# Conclusions

We developed a conceptual framework to illustrate national priorities for future research to reduce the risk of primary breast cancer in women (see Figure 4). According to stakeholders, the highest priority research areas for the prevention of breast cancer are:

1. Population—understanding which populations are at highest risk of breast cancer, most likely to experience benefit, and least likely to be harmed by therapy (Question A).
2. Intervention—broadening the scope on interventions (beyond medications) and comparative effectiveness research to include factors such as lifestyle, diet and exercise (Question B).
3. Influencing factors—understanding influences such as health system factors, communication, education, dissemination of high quality information into clinical practice and to patients, and decisionmaking on initiation, continuation, and responses of preventive therapies (Question C).
4. Integration of biological markers across the spectrum of research relating to breast cancer, understanding populations that are most likely to benefit from therapy, and monitoring response to therapy (integrated in Questions A, B, and C).

For two of these high-priority topics—intervention (Question B) and influencing factors (Question C)—an evidence review could help inform and guide research in these areas, and preliminary searches indicate there is likely to be a sufficient literature.

In general, we found that the traditional analytic framework used to structure reviews does not adequately address future research needs. However, with some adjustments to highlight major areas for research and the addition of biological and influencing factors, we were able to develop a conceptual framework to illustrate national priorities for future research.

Secondarily, we learned important lessons regarding stakeholder engagement. For various reasons, not all stakeholders will be able or willing to participate in a future research needs investigation. Having a list of multiple stakeholders for each stakeholder category is important to ensure sufficient numbers of responses in each category. Other important approaches to successful stakeholder recruitment and engagement include: making personal connections with stakeholders, stakeholders acting as advocates and recruiters for the project contacting potential stakeholders through multiple venues, and being persistent in outreach, referral requests, and followup.

Due to time constraints, we were unable to follow up with stakeholders to verify summary results. During the public posting of the report, we plan to verify results with stakeholders and consider other public comments for revision of this white paper. The results presented are the high-priority areas for research captured from responses in questionnaires similar to the Institute of Medicine CER priority list,333 and they require further development to be actionable research protocols. While questionnaires are effective methods to equitably represent priorities, they are not an optimal format for the creative process of research study design and development. In-person discussions through meetings, focus groups, and panels where conversations and options could be explored and developed are more conducive to study design and protocol development. The information from this report, particularly the conceptual framework and Table 7 (Future Research Agenda for Breast Cancer Prevention) provides a solid foundation for such discussions to expand and detail the specific research needs to advance this field of study.