# Background

Breast cancer is the second most commonly diagnosed cancer in women in the United States, with over 200,000 new cases of invasive breast cancer expected in women in 2010.^1^ It is the second most common cause of cancer-related death in women, killing over 40,000 women each year.1 Tamoxifen was approved by the U.S. Food and Drug Administration (FDA) in 1999 as a preventive strategy for women at high risk of developing breast cancer. Data from the 2000 National Health Interview Survey estimated that 10 million U.S. women ages 35 to 79 years of age were candidates for tamoxifen preventive therapy and for 2.4 million of these women, the benefits would outweigh the harms.2 However, despite its approval for more than a decade, less than one percent of women use tamoxifen as a preventive therapy.3 In 2007, the FDA approved the use of raloxifene hydrochloride for reduction in the risk of invasive breast cancer in postmenopausal women with osteoporosis and/or at high risk for invasive breast cancer.4

In 2008, the Agency for Healthcare Research and Quality (AHRQ) commissioned the Oregon Evidence-based Practice Center (Oregon EPC) to conduct a comparative effectiveness review (CER) on the effectiveness of medications to reduce the risk of primary breast cancer in women.2,3 Briefly, the five key questions addressed by the review were:

1. In adult women without preexisting breast cancer, what is the comparative effectiveness of selective estrogen receptor modulators (SERMs) tamoxifen and raloxifene, and the selective tissue estrogenic activity regulator (STEAR) tibolone, when used to reduce risk for primary breast cancer on improving short-term and long-term outcomes?
2. What is the evidence for harms?
3. How do outcomes vary by heterogeneity in subpopulations?
4. What is the evidence that harms or secondary potential benefits affect treatment choice, concordance, adherence, and persistence to treatment?
5. What methods, such as clinical risk-assessment models, have been used to identify women who could benefit from medications to reduce risk of breast cancer?

Figure 1 depicts the analytic framework for the target population, interventions, and outcomes of the CER.

Figure 1 CER analytic framework

Note: Numbers refer to key questions.

This flowchart presents the analytic framework for the target population, interventions, and outcomes of the CER. A series of five key questions are asked at appropriate stages of the framework. The target population is “women without preexisting cancer”; key question no.5 is used to select candidates for therapy. The therapy at issue, “use of medications to reduce risk of breast cancer,” is assessed through key questions 1 through 4. Key questions 1, 3, and 4 yield information about reduced incidence of breast cancer (invasive and noninvasive) and fractures, and ultimately about improved breast cancer and all-cause mortality. Key question 2, 3, and 4 yield information about the adverse effects of medications.

The CER found that two selective estrogen receptor modulators (SERMs), tamoxifen citrate (RR, 0.70; 95% CI, 0.59 to 0.82; 4 trials) and raloxifene (RR, 0.44; CI, 0.27 to 0.71; 2 trials), were effective to reduce the risk of invasive breast cancer in women without preexisting cancer. However, the CER also found that the medications have important adverse effects.

## Research Gaps

The CER identified a number of research gaps and limitations (Appendix A).2,3 These are summarized below, and categorized according to the most applicable element of the population, intervention, comparator, and outcome (PICO) framework:4

Population | - Evaluation in population subgroups (e.g., nonwhite women, premenopausal women, and women who have comorbid conditions or are taking additional medications for other indications); - Determination of the optimal candidates for risk-reduction medications; - Evaluation of clinical risk instruments to identify high-risk women who are most likely to benefit from risk reducing interventions; - Clearer identification of the characteristics of patients who experience specific adverse effects.
Intervention | - Determination of optimal doses, duration of treatment, timing of medication use, and adherence to treatment; - Additional evaluation of tibolone; - Trials of other emerging medications to reduce breast cancer risk, such as aromatase inhibitors and retinoids; - Trials of strategies to optimize benefits and minimize harms, such as the concurrent use of a SERM and an anticoagulant; - Controlled trials of lifestyle modification interventions to reduce risk for breast cancer, such as weight loss and exercise.
Comparator | - Head-to-head comparison trials, including trials with tibolone
Outcome | - Evaluation of persistence of effects after treatment; - Long-term tracking of outcomes; - Further analysis of currently available trial data to evaluate differences in the net impact (risk/benefit) for women of various ages and risk groups; - Adequate ascertainment and power to detect statistical differences in adverse outcomes.
Other | - Understanding the physician and patient decisionmaking process, including optimal methods for communicating risk and attitudes.

## Objective

The objective of this pilot project was to engage stakeholders to develop and prioritize a list of research questions to reduce the risk of primary breast cancer. Our goal was to provide sufficient detail—including population, intervention, comparator, and outcome (PICO)—for researchers and funders to use in the development of research proposals and solicitations, respectively. Secondarily, this project was intended to identify a feasible and effective approach to identify and prioritize future research from systematic reviews in general.