# Appendixes

Appendix A CER Section on Future Research Needs

Appendix B Future Research Agenda Questionnaire I: Consumer/Policymaker

Appendix C Future Research Agenda Questionnaire II: Clinician/Research Funder/Researcher

Appendix D Search Strategy for Ongoing Studies