# Search Strategy for Ongoing Studies

## Clinical Trials, Searched 7/14/2010

ClinicalTrials.gov

(breast cancer risk [DISEASE] AND ( tamoxifen OR raloxifene OR tibolone ) [TREATMENT]) OR (breast cancer chemoprevention [ALL-FIELDS]) (81 results)

searched 7/14/2010

breast cancer prevention [ALL-FIELDS] (316 results)

Current Controlled Trials

breast cancer chemoprevention (one result)

tamoxifen (35 results only 2 related to breast cancer risk reduction)

ralozifene (no unique results)

tibolone (no unique results)

searched 7/14/2010

breast cancer prevention (one unique result)

Clinical Study Results

[no results for tamoxifen, raloxifene or tibolone]

searched 7/14/2010

breast cancer prevention [no results]

WHO Clinical Trials

(tamoxifen OR raloxifen OR tibolone) AND breast cancer risk (319 results, only 7 unique items related to breast cancer risk reduction were added)

searched 7/14/2010

breast cancer prevention (26 results, 2 unique items)

## Citation Search to find articles that have cited the review—Searched 7/14/2010

Scopus 3 articles found

Google Scholar 5 articles found (2 unique)

Annals of Internal Medicine Website 2 articles found (1 unique)

## Reproduction of original search—Searched from January 2009 to current

MEDLINE 1996 to June Week 4 Searched 7/7/2010

# | Searches | Results
1 | (ovar$ adj5 (cancer$ or tumor$ or malignan$ or carcino$ or neoplas$)).mp. | 33906
2 | exp tamoxifen/ | 9988
3 | exp raloxifene/ | 1818
4 | 2 or 3 | 9988
5 | 1 and 4 | 270
6 | limit 5 to humans | 245
7 | limit 6 to yr=“2009 -Current” | 21

# | Searches | Results
1 | exp tamoxifen/ | 9988
2 | exp raloxifene/ | 1818
3 | 1 or 2 | 9988
4 | exp tamoxifen/ae, po, to | 1821
5 | exp raloxifene/ae, po, to | 230
6 | 4 or 5 | 1821
7 | exp genital diseases, female/ci, ep, et | 30430
8 | exp genital diseases, female/ | 130131
9 | 6 and 8 | 630
10 | 3 and 7 | 645
11 | 9 or 10 | 724
12 | 3 and 8 | 1044
13 | 12 not 11 | 320
14 | limit 13 to yr=“2009 -Current” | 23

# | Searches | Results
1 | tamoxifen/ae, po, to | 1635
2 | exp raloxifene/ae, po, to | 230
3 | 1 or 2 | 1801
4 | exp uterine diseases/ | 49051
5 | exp uterus/ | 29657
6 | 4 or 5 | 70631
7 | 3 and 6 | 610
8 | exp hysterectomy/ | 8836
9 | 3 and 8 | 37
10 | 7 or 9 | 616
11 | limit 10 to (english language and humans) | 528
12 | limit 11 to yr=“2009 -Current” | 15

# | Searches | Results
1 | selective estrogen receptor modulators/ or raloxifene/ or tamoxifen.mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | 13705
2 | exp breast neoplasms/pc | 6517
3 | 1 and 2 | 1021
4 | primary prevention/ | 8310
5 | (primar$ adj2 prevent$).mp. | 14372
6 | exp breast neoplasms/ | 101219
7 | 1 and 4 and 6 | 34
8 | chemoprevention/ | 2678
9 | chemoprevent$.mp. | 11095
10 | 1 and 6 and 9 | 411
11 | 1 and 5 and 6 | 77
12 | 10 or 11 | 457
13 | (prevent$ adj3 (breast$ adj2 (neoplas$ or tumor$ or cancer$ or malignan$))).mp. | 1668
14 | 1 and 13 | 675
15 | 6 and 14 | 594
16 | 12 or 15 | 855
17 | limit 16 to humans | 847
18 | limit 17 to english language | 795
19 | limit 17 to abstracts | 701
20 | 18 or 19 | 831
21 | limit 20 to yr=“2009 -Current” | 36

# | Searches | Results
1 | tibolone.mp. | 787
2 | exp breast neoplasms/ | 101219
3 | exp breast/ | 12793
4 | 2 or 3 | 106836
5 | 1 and 4 | 150
6 | 1 not 5 | 637
7 | limit 6 to yr=“2009 -Current” | 44

# | Searches | Results
1 | exp tamoxifen/ae, po, ct, to | 1827
2 | exp raloxifene/ae, ct, to | 231
3 | selective estrogen receptor modulators/ae, co, to, po | 376
4 | 1 or 2 or 3 | 1948
5 | exp cardiovascular diseases/mo, ci, co, ep, et | 334514
6 | exp stroke/mo, co, ci, ep, et | 25812
7 | exp cardiovascular system/pp, de | 97774
8 | 5 or 6 or 7 | 414246
9 | 4 and 8 | 177
10 | exp cardiovascular system/ | 355700
11 | exp cardiovascular diseases/ | 718165
12 | 10 or 11 | 895463
13 | exp tamoxifen/ | 9988
14 | exp raloxifene/ | 1818
15 | selective estrogen receptor modulators/ | 2594
16 | 13 or 14 or 15 | 10910
17 | 4 and 12 | 197
18 | 8 and 16 | 560
19 | 17 or 18 | 580
20 | limit 9 to humans | 176
21 | limit 19 to humans | 432
22 | 21 not 20 | 256
23 | 12 and 16 | 846
24 | limit 23 to humans | 618
25 | 24 not 21 | 186
26 | (2009$ or 2010$).ed. | 1054711
27 | 12 and 16 | 846
28 | 26 and 27 | 71

# | Searches | Results
1 | exp breast neoplasms/ | 101219
2 | exp risk/ | 455470
3 | 1 and 2 | 13514
4 | exp risk assessment/ | 108692
5 | 1 and 4 | 3271
6 | limit 5 to humans | 3262
7 | exp breast neoplasms/ep, et | 10531
8 | 4 and 7 | 1164
9 | exp breast neoplasms/pc, eh | 7858
10 | exp breast neoplasms/ge | 18582
11 | 4 and 9 | 669
12 | 4 and 10 | 840
13 | exp disease susceptibility/ | 65653
14 | 7 and 13 | 893
15 | 9 and 13 | 564
16 | 8 or 11 or 14 or 15 | 2664
17 | limit 16 to english language | 2517
18 | (model$ or valid$).mp. | 1332255
19 | 17 and 18 | 711
20 | seer.mp. | 2733
21 | 17 and 20 | 47
22 | 19 or 21 | 739
23 | limit 22 to yr=“2009 -Current” | 107

# | Searches | Results
1 | tibolone.mp. | 787
2 | exp breast neoplasms/ | 101219
3 | exp breast/ | 12793
4 | 2 or 3 | 106836
5 | 1 and 4 | 150
6 | limit 5 to yr=“2009 -Current” | 10

# | Searches | Results
1 | exp tamoxifen/ | 9988
2 | exp raloxifene/ | 1818
3 | 1 or 2 | 9988
4 | exp tamoxifen/ae, po, to | 1821
5 | exp raloxifene/ae, po, to | 230
6 | 4 or 5 | 1821
7 | exp genital diseases, female/ci, ep, et | 30430
8 | exp genital diseases, female/ | 130131
9 | 6 and 8 | 630
10 | 3 and 7 | 645
11 | 9 or 10 | 724
12 | 3 and 8 | 1044
13 | 12 not 11 | 320
14 | limit 13 to yr=“2009 -Current” | 23

EBM Reviews—Cochrane Central Register of Controlled Trials 2nd Quarter 2010 Searched 7/7/2010

# | Searches | Results
1 | tibolone.mp. | 368
2 | limit 1 to yr=“2009 -Current” | 12

# | Searches | Results
1 | ((tamoxifen or raloxifene) adj5 (endometri$ or uterine or uterus or hysterec$)).mp. | 198
2 | limit 1 to yr=“2009 -Current” | 6

# | Searches | Results
1 | tamoxifen.mp. | 2634
2 | raloxifene.mp. | 460
3 | placebo$.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] | 118412
4 | 1 and 2 | 31
5 | 1 and 3 | 337
6 | 2 and 3 | 252
7 | 4 or 5 or 6 | 592
8 | ((breast$ or mammar$) adj5 (cancer$ or tumor$ or carcino$ or adenocarcin$ or neoplas$ or malignan$)).mp. | 11674
9 | 7 and 8 | 302
10 | limit 9 to yr=“2009 -Current” | 12

EBM Reviews—Cochrane Database of Systematic Reviews 2005 to May 2010 Searched 7/7/2010

# | Searches | Results
1 | tamoxifen.mp. | 54
2 | raloxifene.mp. | 9
3 | placebo@.mp. | 3999
4 | 1 and 2 | 3
5 | 1 and 3 | 37
6 | 2 and 3 | 9
7 | 4 or 5 or 6 | 43
8 | ((breast$ or mammar$) adj5 (cancer$ or tumor$ or carcino$ or adenocarcin$ or neoplas$ or malignan$)).mp. | 239
9 | 7 and 8 | 19
10 | limit 9 to last 2 years | 11

# | Searches | Results
1 | tibolone.mp. | 11
2 | limit 1 to last 2 years | 6

# | Searches | Results
1 | ((tamoxifen or raloxifene) adj5 (endometri$ or uterine or uterus or hysterect$)).mp. | 7
2 | limit 1 to last 2 years | 4

EBM Reviews—Database of Abstracts of Reviews of Effects 2nd Quarter 2010 Searched 7/7/2010

# | Searches | Results
1 | ((tamoxifen or raloxifene) adj5 (endometri$ or uterine or uterus or hysterect$)).mp. | 5
2 | limit 1 to last 2 years | 5

# | Searches | Results
1 | tamoxifen.mp. | 52
2 | raloxifene.mp. | 15
3 | placebo$.mp. | 2557
4 | 1 and 2 | 7
5 | 1 and 3 | 16
6 | 2 and 3 | 9
7 | 4 or 5 or 6 | 22
8 | ((breast$ or mammar$) adj5 (cancer$ or tumor$ or carcino$ or adenocarcin$ or neoplas$ or malignan$)).mp. | 376
9 | 7 and 8 | 16
10 | limit 9 to last 2 years | 16

# | Searches | Results
1 | tibolone.mp. | 6
2 | limit 1 to last 2 years | 6

## Grants—searched 7/14/2010

NIH RePORTER

breast cancer chemoprevention (136 results)

breast cancer risk reduction (112 results)

HSRProj

breast cancer chemoprevention (8 results)

AHRQ GOLD

breast cancer (no unique results)

## The following Web sites of funding agencies were searched directly on 7/14/2010 & 7/15/2010

Alaska Run for Women

http://www.akrfw.org/grants_10.htm

American Association for Cancer Research

http://www.aacr.org/home/scientists/research-funding--fellowships.aspx

American Cancer Society

http://www.cancer.org/Research/index

American Society of Clinical Oncology

http://www.asco.org/ASCOv2/Research+Resources/Grants+%26+Awards

ASCO Cancer Foundation

http://www.ascocancerfoundation.org/TACF/Grants/Grant+Recipients/Young+Investigator+Award

Avon Foundation

http://www.avonfoundation.org/funding-and-grants/avon-foundation-funding-history.html

Baldwin Breast Cancer Research Fund, Inc., Carol M.

http://www.findacure.org/grants_awarded.html

Blue Cross and Blue Shield of North Carolina Foundation

http://www.bcbsncfoundation.org/grants/

Breast Cancer Research Foundation

http://www.bcrfcure.org/

DTIC Online—Public Scientific & Technical Information

http://www.dtic.mil/

Flight Attendant Medical Research Institute, Inc.

http://www.famri.org/researchers/awards_history.html

Foundation, Mary Kay

http://www.mkacf.org/Pages/GrantRecipients_2009.aspx

HealthCare Foundation for Orange County, The

http://www.hfoc.org/index.jsp

Howard Hughes Medical Institute

http://www.hhmi.org/research/search.html

Komen Foundation

http://ww5.komen.org/researchgrantsawarded.aspx?id=16252

Dr. Susan Love Research Foundation

http://www.dslrf.org/breastcancer/content.asp?L2=1&L3=2&SID=125

National Cancer Institute

http://www.cancer.gov/clinicaltrials/search

Noreen Fraser Foundation

http://www.noreenfraserfoundation.org/about/grants/

Premera CARES Program

https://www.premera.com/stellent/groups/public/documents/xcpproject/abt_giving_wa.asp

Rosenberg Foundation, Inc., Henry and Ruth Blaustein, The

http://www.blaufund.org/foundations/henryruthgrant_2009.html#3

Wawa, Inc. Corporate Giving Program

http://www.wawa.com/wawaweb/Charity.aspx

Wellcome Trust

http://www.wellcome.ac.uk/Funding/Grants-awarded/index.htm

Women’s Funding Alliance

http://www.wfalliance.org/impact/recentgrants.php