# Abbreviations

AHRQ: Agency for Healthcare Research and Quality
CER: Comparative Effectiveness Review(s)
DIM: Diindolylmethane
ER: Estrogen receptor
EPC: Evidence-based Practice Center
I PICO: Influencing factors, Population, Intervention, Comparator, Outcome
NIH: National Institutes of Health
PICO: Population, Intervention, Comparator, Outcome
SERM: Selective estrogen receptor modulator
SNP: Single nucleotide polymorphism
STAR: Study of Tamoxifen and Raloxifene
STEAR: Selective tissue estrogenic activity regulator