# Results

## Research Needs

### Prioritization Results

Many stakeholders raised the important question of whether research should continue to compare the relative effectiveness of HCBS and NH care given the changes in social thinking that have occurred and the preference in most cases for HCBS. Stakeholders discussed a number of research questions about HCBS and NH care that they felt are relevant but do not compare the relative effectiveness of HCBS and NH care. In order to address the issues that stakeholders felt are most important for future research on LTC for older adults, we grouped research questions into two major sets, each of which was further divided into methodological questions and topical questions. The first set addressed the comparison of LTC delivered through HCBS and in NHs. The second set addressed broader LTC issues by treating HCBS and NHs separately, rather than as a comparison. Stakeholders separately ranked methodological and topical research questions for the two sets of identified research questions. We discuss results for each set of ranked questions. A total of 10 stakeholders, out of the 13 who were invited to participate, completed the ranking exercise. Participating stakeholders included representatives from all groups that we engaged in the process. We analyzed weighted stakeholder rankings for each research question to identify breakpoints (Tables 1 and 2). High-priority methodological research questions and high-priority topical research questions were deemed research needs.

Table 1 Stakeholder prioritization of research gap questions about the benefits and costs of care delivered through HCBS versus NHs

Research Gap Questions | Ranking Total (Points)^*^
Methodological Questions (n=10)
Tier 1: High Priority
What standardized outcome measures should be used for HCBS and NH recipients that fully measure benefits and harms and are capable of showing meaningful change? | 8 (19)
Tier 2: Moderate/Low Priority
How should we characterize the settings and services and the composition of persons served for the intervention? | 4 (11)
What sources of payment for HCBS should be included to assure a fair comparison of costs? | 4 (8)
How should floor and ceiling effects be taken into account when examining decline in certain outcomes like function or cognition? | 5 (7)
How should attrition be dealt with, particularly attrition due to death? | 4 (6)
How should we adjust for selection bias (methods such as propensity scores, instrumental variables, and “ideal types”)? | 3 (6)
How should we account for persons moving from one type of care to another? | 2 (3)

Topical Questions (n=10) | Total (Points)^*^ | PICOTS Element
Tier 1: High Priority
What is the pattern of transitions of LTC users? What factors lead to transitions? | 6 (6) | P, O
Tier 2: Moderate/Low Priority
How does HCBS versus NH care differ for subgroups? | 2 (2)
What are the benefits and costs of HCBS versus NH care for non-Medicaid recipients? | 2 (2)

HCBS = home and community-based services; LTC = long-term care; NA = not applicable; NH = nursing home

* The first number reflects the total number of individuals who ranked the item. The second number (in parentheses) reports the weighted total point score. For the methodological topics, stakeholders ranked their top 3 priorities so the total point score was created by assigning questions ranked #1 by stakeholders with 3 points, #2 by stakeholders with 2 points, and #3 by stakeholders with 1 point. . For the topical questions, stakeholders ranked their top 1 priority so the total point score was created by assigning the question ranked #1 by stakeholders with 1 point.

Table 2 Stakeholder prioritization of research gap questions about LTC through HCBS and in NHs

Research Gap Questions Ranking | Ranking Total (Points)^*^
Methodological Questions (n=10)
Tier 1: High Priority
What should be included in a taxonomy of HCBS and how do we measure a 'service' to enable research across different types of HCBS? | 6 (17)
What is the minimum set of potential outcomes for HCBS and NH recipients? For example, outcomes may include abuse, loneliness as an intermediate outcome that could predict institutionalization, transitions (likelihood of being discharged from a NH after an individual enters a NH, likelihood of going back to a NH after discharge from the NH, and likelihood of being rehospitalized after experiencing a hospitalization). | 4 (16)
What quality-of-life measures and disease specific measures should be used to capture an individual's experience in LTC? | 6 (14)
What should be included in a taxonomy for assisted living to assess the effectiveness of services and to compare to other HCBS? | 4 (12)
Tier 2: Moderate/Low Priority
How should ADLs and IADLs be measured to accurately assess service needs and outcomes within different environments? | 3 (9)
Which set of marginal benefits and marginal costs of the care should be assessed in HCBS research? | 4 (8)
What can be added to current administrative data or surveys to facilitate research on LTC? | 5 (7)
What information do we need to develop better risk adjusters in order to make comparisons across different HCBS programs? | 3 (7)
How do we collect and combine information across all transitions in LTC? | 3 (6)
What could be used as a standardized tool to collect case-mix and outcomes data on HCBS recipients? For example, can the Medicare CARE Tool be used for HCBS programs? | 1 (3)
What sources of payment for HCBS should be included to assure a fair comparison of costs? | 1 (1)

Topical Questions (n=10) | Total (Points)^*^ | PICOTS Element
Tier 1: High Priority
What works for whom? How does HCBS affect different subpopulations/subgroups? | 7 (27) | P, I
How do outcomes of individuals in managed care programs differ from those of individuals in fee-for-service programs? Do managed LTC programs for dual eligibles offload costs onto Medicare? | 9 (26) | P, I, O
What services within HCBS result in better outcomes for individuals? | 6 (21) | I
How do policies, payment rates, and availability of services in different areas impact who does or does not receive HCBS? | 5 (19) | P, S
Tier 2: Moderate/Low Priority
How does increasing burden on families affect individuals staying in home and community settings? | 5 (14)
What is the pattern of hospital admissions and readmissions for LTC users in various settings? | 5 (13)
What is the pattern of transitions of LTC users? What factors lead to transitions? | 4 (13)
How does staff turnover in different settings impact quality of care for LTC recipients? | 3 (7)
Can case management improve HCBS outcomes? | 3 (4)
How is training of the workforce related to quality of care in HCBS? (There is variation across settings in what services are being delivered and how the services are implemented by care providers.) | 1 (3)
How does NH environment and design affect quality of care and health outcomes of residents? | 1 (2)
What is the use and role of technology (for information and assistance) in LTC? How does it impact outcomes? | 1 (1)

LTC = long-term care; HCBS = home and community-based services; NA = not applicable; NH = nursing home

* The first number reflects the total number of individuals who ranked the item. The second number (in parentheses) reports the weighted total point score. For the methodological topics, stakeholders ranked their top 4 priorities so the total point score was created by assigning questions ranked #1 by stakeholders with 4 points, #2 by stakeholders with 3 points, #3 by stakeholders with 2 points, and #4 by stakeholders with 1 point. For the topical questions, stakeholders ranked their top 5 priorities so the total point score was created by assigning the question ranked #1 by stakeholders with 5 points, #2 by stakeholders with 4 points, #3 by stakeholders with 3 points, #4 by stakeholders with 2 points, and #5 by stakeholders with 1 point.

## Methodological Research Needs

Among the methodological questions for the comparison of LTC delivered through HCBS and in NHs, the identification of standardized outcome measures for HCBS and NH recipients was the number one priority. Eight out of 10 stakeholders ranked this as a priority. The rankings of six other methodological questions for the comparison of LTC delivered through HCBS and in NHs ranked much lower than the top tier. For the broader set of methodological questions about LTC through HCBS and in NHs, four questions related to outcome measures and descriptions of the interventions ranked highly compared with the other seven questions.

- What standardized outcome measures should be used for HCBS and NH recipients that fully measure benefits and harms and are capable of showing meaningful change?
- What should be included in a taxonomy of HCBS and how do we measure a “service” to enable research across different types of HCBS?
- What is the minimum set of potential outcomes for HCBS and NH recipients? For example, outcomes may include abuse, loneliness (as an intermediate outcome that could predict institutionalization), and transitions (likelihood of being discharged from a NH after an individual enters a NH, likelihood of going back to a NH after discharge from the NH, and likelihood of being rehospitalized after experiencing a hospitalization).
- What quality-of-life measures and disease specific measures should be used to capture an individual's experience in LTC?
- What should be included in a taxonomy for assisted living to assess the effectiveness of services and to compare to other HCBS?

Addressing methodological research needs will enhance the utility of future research on LTC for older adults. The methodological research needs identified by stakeholders as the highest priorities pertain to the outcome measures that are appropriate within these care settings and important to care recipients and to the definition of services that individuals receive.

The CER highlighted that the variation in outcome measures and data collection used across studies made it difficult to compare results. The differences in care environments, including which measurements are used and who collects the data, may affect results. These differences can make it challenging to determine whether different effects across different studies are due to outcome measurement issues or other issues. Stakeholders emphasized the importance of finding standardized outcome measures. Additionally, the CER and stakeholders stressed the importance of examining outcomes that measure an individual's experience across multiple domains, including outcomes that are most important to individuals when they choose between care settings. There was insufficient evidence for most outcomes examined in the CER, including outcomes related to quality-of-life and experience of care. Consensus on outcome measures would improve future research and the ability to understand how different types of LTC affect outcomes of older adults.

The CER emphasized that most studies did not sufficiently describe the settings and services received, and few studies specified the type, frequency, or intensity of services. The nature of HCBS and AL services can vary widely, so a description of services is necessary to judge applicability. Our discussions with stakeholders, and the results of the ranking process, indicate that creating and using a standardized taxonomy for HCBS and AL is important to understanding research on these types of care. CMS has been working with contractors to produce a taxonomy of services (www.nasuad.org/documentation/hcbs2011/Presentations/W10RegencyA.pdf). Using this taxonomy in future research will increase the usefulness and comparability of research efforts.

## Topical Research Needs

The highest priority ranked among the topical gaps for the comparison of LTC delivered through HCBS and in NHs related to the pattern of transitions and the factors leading to transitions for LTC users. We also identified four high priority topical questions to address for LTC delivered through HCBS and in NHs. All topical research needs primarily addressed populations and interventions.

- What is the pattern of transitions of LTC users? What factors lead to transitions?
- What works for whom? How does HCBS affect different subpopulations/subgroups?
- How do outcomes of individuals in managed care programs differ from those of individuals in fee-for-service programs? Do managed LTC programs for dual eligibles offload costs onto Medicare?
- What services within HCBS result in better outcomes for individuals?
- How do policies, payment rates, and availability of services in different areas impact who does or does not receive HCBS?

LTC users commonly transition through different settings as needs and preferences change, but evidence from the CER suggests that these transitions are rarely characterized or modeled in studies. Studies infrequently follow individuals as they move in and out of different settings, and they are often not explicit about individuals' transitions over time or factors that led to transitions. Stakeholders indicated that understanding LTC users' transitions would help us develop interventions to avoid or improve transitions.

No studies evaluated in the CER addressed outcomes for subgroups. Stakeholders rated the understanding of the efficacy of different interventions for different subgroups as an important priority. Subgroups might be defined by characteristics such as race/ethnicity, socioeconomic status, and diagnoses. In our discussions, many stakeholders indicated the need to better understand managed LTC programs, including how outcomes and costs compare for managed LTC users compared to fee-for-service users. From a policy and payer perspective, this resonated as a particularly salient research question.

Stakeholders were particularly interested in understanding how different services within the package of HCBS improve outcome trajectories for individuals. They were also interested in how the policy and payment environment affects HCBS and NH use. These topics were rated as high priorities to address in future research.

## Considerations for Potential Research Designs

Randomization is an issue across all topical research needs. Randomization to HCBS versus NH or to AL versus NH is generally precluded for practical and ethical reasons. Those with a strong preference for community care would not likely accept a NH placement, and many individuals who believe they need NH care have already decided to enter a NH. However, stakeholders suggested that RCTs could be used to compare the effects of variations of HCBS. Randomization would allow for more robust research about the efficacy of different types of services within HCBS and about the efficacy of HCBS for different subgroups. The possibility of a strong sampling bias in who agrees to be randomized remains, raising questions about applicability.

Cohort studies, alternatively, are less resource-intensive and produce applicable results. Longitudinal cohort studies follow individuals over a period of time and would be practical to examine the outcome trajectories of LTC users. Large sample sizes will be necessary to allow for subgroup and interaction analyses, but this is easier to attain in cohort studies than in RCTs. An LTC admission cohort with a prospective cohort design would allow researchers to understand how interventions may modify the outcome trajectories over time. The ability of this design to assess differences can be improved by using consistent measures and observation schedules, collected by independent observers.

Studies need to use statistical techniques to adjust for selection to ensure that the comparisons between groups are unbiased. These techniques include multivariate analysis, propensity scores, instrumental variables, and frontier analysis.5 Frontier analysis identifies groups with specific clusters of key patient characteristics that pertain to a specific health issue. Factors considered for adjustment should include LTC attitudes held by both clinicians and consumers and availability of informal support. Studies should adjust for case mix and account for changes in the composition of the populations that result from deaths or transfers to different settings.

In discussions with stakeholders, other research design considerations that were mentioned included the need for studies with more generalizable samples and populations of private-pay LTC users.

Tables 3-7 discuss study design elements by specific identified topical research need.

Table 3 Design considerations: What is the pattern of transitions of LTC user? What factors lead to the transitions?

Design Element | Proposed Approach
Research design | Observational studies will be needed; cohort design; randomization is not feasible
Ethical issues | None anticipated
Availability of data; recruitment | Can use linked files from administrative data sets such as Medicaid (MAX), Medicare, Nursing Home Minimum Data Sets (MDS). Other data such as state spending or private pay may not be available.
Population | Persons enrolled in HCBS programs (could separate waiver users from state plan users); important to include private pay individuals where possible. Given the emphasis on facilitating discharges from nursing homes, one could likewise trace those who are discharged at various lengths of stay and assess what factors are associated with remaining in the community.
Intervention | Not applicable
Comparator | Not applicable
Outcomes | Subsequent use of LTC services, especially nursing home readmissions, hospitalizations
Timing | At least one year of follow up; more is better

HCBS = home and community-based services; LTC = long-term care

Table 4 Design considerations: What works for whom? How does HCBS affect different subpopulations/subgroups?

Design Element | Proposed Approach
Research design | Observational studies will be needed; cohort design; randomization is not feasible
Ethical issues | None anticipated
Availability of data; recruitment | Can use linked files from administrative data sets such as Medicaid (MAX), Medicare, Nursing Home Minimum Data Sets (MDS). Other data such as state spending or private pay may not be available.
Population | Persons enrolled in HCBS programs (could separate waiver users from state plan users); important to include private pay individuals where possible Identify subgroups based on ADLs, cognition, comorbidities, informal care support, possibly ethnicity and SES
Intervention | Different HCBS arrangements (type of support, amount)
Comparator | Not applicable
Outcomes | Trajectory of ADL and cognitive status Subsequent use of LTC services; use of medical services such as ERs and hospitalizations
Timing | At least one year of followup; more is better

ADL = activities of daily living; HCBS = home and community-based services; LTC = long-term care; SES = socioeconomic status

Table 5 Design considerations: How do outcomes of individuals in managed care programs differ from those of individuals in fee-for-service programs? Do managed LTC programs for dual eligibles offload costs onto Medicare?

Design Element | Proposed Approach
Research design | Observational studies will be needed; cohort design; randomization is not feasible
Ethical issues | None anticipated
Availability of data; recruitment | Can use linked files from Medicaid (MAX) administrative data sets for non-managed care; need cooperation of managed care organizations to make data available
Population | Persons enrolled in HCBS programs (could separate waiver users from state plan users) in managed care Separate analysis for persons who are dually eligible for Medicare and Medicaid (likely to be the majority of older people)
Intervention | Managed care
Comparator | Persons enrolled in HCBS programs (could separate waiver users from state plan users) in traditional fee-for-service arrangements
Outcomes | Trajectory of ADL and cognitive status Subsequent use of LTC services; use of medical services such as ERs and hospitalizations
Timing | At least one year of followup; more is better

ADL = activities of daily living; ER = emergency room; HCBS = home and community-based services; LTC = long-term care

Table 6 Design considerations: What services within HCBS result in better outcomes for individuals?

Design Element | Proposed Approach
Research design | Observational studies will be needed; cohort design; randomization may be possible in limited circumstances
Ethical issues | None anticipated
Availability of data; recruitment | Can use linked files from administrative data sets such as Medicaid (MAX), Medicare, Nursing Home Minimum Data Sets (MDS). Other data such as state spending or private pay may not be available Applicability would likely be constrained for randomized studies due to the strong possibility of sampling bias
Population | Persons enrolled in HCBS programs (could separate waiver users from state plan users); important to include private pay individuals where possible
Intervention | Classification of HCBS services
Comparator | Not applicable
Outcomes | Trajectory of ADL and cognitive status Subsequent use of LTC services; use of medical services such as ERs and hospitalizations
Timing | At least one year of followup; more is better

ADL = activities of daily living; ER = emergency room; HCBS = home and community-based services; LTC = long-term care

Table 7 Design considerations: How do policies, payment rates, and availability of services in different areas impact who does or does not receive HCBS?

Design Element | Proposed Approach
Research design | Observational studies will be needed; cohort design; randomization is not feasible The ideal design would examine those who do and do not get HCBS, but a compromise may be to look only at those who do get HCBS and describe variation in composition of recipients by state policies, payment rates, and availability of services
Ethical issues | None anticipated
Availability of data; recruitment | The challenge in this study will be identifying prisons who would qualify for HCBS but do not receive it. Can use linked files from Medicaid (MAX) administrative data sets for persons getting HCBS but may need an independent survey to identify eligible non-recipients and compare patterns by state policies, payment rates, and availability of services Limited data on service availability in area resource files; may need to do a separate survey
Population | Persons enrolled in HCBS programs (could separate waiver users from state plan users) Persons not in HCBS
Intervention | State policies, payment rates, and availability of services
Comparator | Not applicable
Outcomes | Receipt of LTC services Characteristics of recipients
Timing | At least one year of followup; more is better

HCBS = home and community-based services; LTC = long-term care