# References

1 Feder J, Komisar HL, Niefeld M. Long-term care in the United States: an overview. Health Affairs. 2000;19(3):40-56. [pmid: 10812780].
2 Kane RA, Kane RL, Ladd RC. The Heart of Long-Term Care. London. Oxford University Press. 1998.
3 O'Haire C, McPheeters M, Nakamoto E, et al. Engaging Stakeholders To Identify and Prioritize Future Research Needs. Methods Future Research Needs Report No. 4. (Prepared by the Oregon Evidence-based Practice Center and the Vanderbilt Evidence-based Practice Center under Contract No. 290-2007-10057-I). AHRQ Publication No. 11-EHC044-EF. Rockville, MD. Agency for Healthcare Research and Quality. June. 2011.
4 SurveyMonkey.com LLC. Palo Alto, CA. 2012. www.surveymonkey.com.
5 Johnson PE, Veazie PJ, Kochevar L, et al. Understanding variation in chronic disease outcomes. Health Care Manag Sci. Aug. 2002;5(3):175-89. [pmid: 12363045].