# Methods

This FRN report identifies and prioritizes specific gaps in the current literature on LTC for older adults to encourage researchers and funders to fill these gaps in order to make the body of evidence more useful to decisionmakers. We used a deliberative process to identify specific research needs and research design considerations. Figure 2 illustrates the eight steps used to accomplish the objectives of this project.

Figure 2 Project flow

CER = comparative effectiveness review

Figure 2 is the project flow diagram. It illustrates the future research needs project process detailed in the Methods section text.

## Engagement of Stakeholders

We recruited a diverse panel of stakeholders panel who represented a variety of perspectives relevant to the topic. We followed guidance on stakeholder engagement for recruitment and communication.3 We sought to recruit stakeholders who were actively involved in research on LTC for older adults or providing LTC for older adults and who wished to help shape future research priorities. We identified potential stakeholders via several means. We sought recommendations from the CER project team, including select Key Informants and Technical Expert Panel members. We sought research representatives who were national experts familiar with evidence-based research and aware of the obstacles faced in conducting well-designed research in health services. We invited representatives from organizations supporting or conducting relevant research and/or programs including the Office of the Assistant Secretary for Planning and Evaluation, the Visiting Nurse Service of New York, LeadingAge and others, as well as policy and payer representation from the Centers for Medicare & Medicaid Services (CMS). We engaged consumer and provider groups, including AARP and the National Center for Assisted Living, because the decisional dilemmas faced by these groups are critical to identifying and prioritizing research questions. Many stakeholders were also involved in the CER process as Key Informants, Technical Expert Panel members, or peer reviewers. A total of 13 stakeholders across these groups responded to our invitation and expressed an interest in participating in this project.

## Handling Conflicts of Interest

We collected disclosures of conflicts of interests from all stakeholders. Disclosed interests did not bar any stakeholders from participation, but allowed the EPC to evaluate contributions based upon possible conflicts. Stakeholders used a Web-based survey to rank specific topical research questions during the prioritization exercise, thus researchers and funders were blind to the others' stated opinions.

## Refinement of Research Gaps

We provided members of our stakeholder panel with a preliminary set of research gaps prior to conference calls. During conference calls, we sought stakeholder input to further refine the research gaps (i.e., organization and wording of the gaps, identification of additional research gaps, and elimination of research gaps with limited value). To facilitate this input, we provided stakeholders in advance with background material including the draft CER executive summary and the Effective Health Care Program Selection Criteria (Appendix A, Appendix B, and Appendix C). We conducted two conference calls with available stakeholders in April 2012. Of the 13 stakeholders who responded to our invitation, 11 were able to participate in the calls. All participants provided input on the calls. We circulated summaries of group calls to all participants, including the two additional stakeholders who were unable to participate in the conference calls. We invited stakeholders to clarify or supplement the call summaries or to suggest additional research questions in response to the call summaries, and one did so via email. We revised the preliminary research gaps based upon these discussions and email communications and phrased the identified gaps as research questions.

Many stakeholders raised the important question of whether research should continue to compare the relative effectiveness of HCBS and NH care given the changes in social thinking that have occurred and the preference in most cases for HCBS. Based on the stakeholder feedback, we grouped research questions into two major sets, each of which was further divided into methodological questions and topical questions. The first set addressed the narrow issue that was the topic of the CER—the comparison of LTC delivered through HCBS and in NHs. The second set addressed broader LTC issues that stakeholders (and reviewers from the CER) raised as salient for the current policy environment. The second set did not frame research questions as a comparison of HCBS and NHs, but rather, treated these settings and services separately.

## Prioritization

We and our stakeholders evaluated the revised set of research questions according to specified criteria. The Effective Health Care Program Selection Criteria provided a starting point (Appendix A), including Current Importance, Potential Impact, Incremental Value, and Feasibility. The Current Importance (Appropriateness) criteria are de facto met because LTC for older adults was accepted as an AHRQ topic.

We addressed redundancy by updating the bibliographic search for the CER through March 2012 and by checking suggested studies from reviewers of the CER.

We then asked stakeholders to rank the research questions focusing on the Potential Impact criteria (i.e., the likelihood that addressing the research gap question would inform clinical practice and policy). We developed a Web-based survey using SurveyMonkey™ to collect stakeholder prioritization of the research gap questions.4 The 13 stakeholders who responded to the stakeholder invitation (9 were non-Federal employees) were invited to rank research questions identified via the stakeholder conference calls. For the first set of research questions addressing the comparison of HCBS with NHs, these stakeholders numerically ranked their top three of seven methodological research questions, and their top one of three topical research questions. For the second set of broader research questions on LTC for older adults, these stakeholders numerically ranked their top 4 of 11 methodological research questions, and their top 5 of 12 topical research questions.

Unweighted scores were calculated based on a count of the number of stakeholders voting for a research question, regardless of the number ranking that they assigned to the research question. Weighted scores were also calculated. Stakeholder rankings were weighted according to their assigned numerical ranking. If a stakeholder assigned a question the number one priority, that question received the highest number of points for that specific set (e.g., for the set where stakeholders ranked their top three priorities, the number one priority received three points and for the set where stakeholders ranked their top four priorities, the number one priority received five points). Each subsequent number ranking was assigned a point value decreasing by one point for each rank. We identified breakpoints in the weighted rankings that separated high and moderate/low priority research questions. Highly prioritized research questions were considered research needs.

We then evaluated the Feasibility criteria for research needs. We framed Feasibility in terms of anticipated research designs. For example, factors that affect the feasibility of conducting randomized controlled trials include the sample size needed for the outcome, the size of the available pool of potential subjects, followup duration, willingness to randomize, and applicability issues. In contrast to randomization and applicability, observational studies face feasibility issues related to measuring study variables using different data sources and unobserved variables that create risk of bias.

## Research Design Considerations

We generated research design considerations for identified research needs. We provided context and described resources and research design considerations potentially useful to researchers, facilitators, and funders of this type of research. For topical research needs, we also highlighted the relevant PICOTS (population, intervention, comparison, outcome, timing, setting) element(s). We did not separately consult with stakeholders for input on research design considerations. However, we incorporated stakeholder feedback from conference calls and email communications that related to research design considerations.