# Executive Summary

## Background

This future research needs (FRN) report is a followup to the 2012 comparative effectiveness review (CER) “Long-Term Care for Older Adults: A Review of Home and Community-Based Services Versus Institutional Care.” The review was intended to support policy and research decisionmaking. FRN projects identify gaps in the current research that limit the conclusions in CERs and inform researchers and research funders about these gaps. They aim to encourage research likely to fill the gaps and make the body of evidence more useful to decisionmakers.

The CER addressed the following two Key Questions targeting direct comparisons of long-term care (LTC) provided through home and community-based services (HCBS) and in nursing homes (NHs) to older adults aged 60 and older:

Key Question 1: What are the benefits and harms of LTC provided through HCBS compared with institutions such as NHs for older adults, aged 60 and older, who need LTC?

a. To what extent do HCBS and NHs serve similar populations?
b. How do the outcomes of the services differ when tested on similar populations?
c. What are the harms to older adults as a result of HCBS and NHs? (Reported harms include accidents, injuries, inadequate preventive care, unnecessary hospitalizations, and concerns about abuse or neglect.)

Key Question 2: What are the costs (at the societal and personal levels) of HCBS and NHs (per recipient and in the aggregate) for adults age 60 and older? Costs may include direct costs of care as well as resource use and family burden.

- Direct costs of care refer to public program and individual spending on LTC services for HCBS recipients and NH residents.
- Resource use includes program and individual spending on acute care services such as physician and hospital care as well as spending by other subsidy or transfer programs.
- Family burden includes the opportunity costs of care.

LTC refers to a broad range of services designed to provide assistance over prolonged periods to compensate for loss of function due to chronic illness or physical or mental disability.1 LTC includes hands-on, direct care as well as general supervisory assistance. HCBS refers to services provided in an array of noninstitutional settings. These include recipients' homes; community-based group-living arrangements such as congregate housing, adult foster care, and residential care and assisted living (AL) facilities (the last two terms are sometimes used interchangeably, but we refer to AL exclusively); and community settings such as adult day care and adult day health. NHs are state-licensed institutional facilities offering 24-hour room and board, supervision, and nursing care.

Results from relevant observational studies were qualitatively synthesized; no relevant randomized controlled trials (RCTs) were identified. The authors found that on average, NH residents had more limitations in physical and cognitive function than both HCBS recipients and AL residents, but mental health and clinical status were mixed. The studies that compared the outcome trajectories of HCBS recipients or AL residents with NH residents over time had high risk of bias, resulting in low or insufficient evidence for all outcomes examined. In comparing AL with NH, low-strength evidence suggested no differences in outcomes for physical function, cognition, mental health, and mortality. In comparing HCBS with NHs, low-strength evidence suggested that HCBS recipients experienced higher rates of some harms while NH residents experienced higher rates of other harms. Evidence was insufficient for other outcome domains and comparisons. Evidence was also insufficient for cost comparisons.

Overall, the CER concluded that it is difficult to determine whether and how the delivery of LTC through HCBS versus NHs affects outcome trajectories of older adults due to scant evidence and the methodological limitations of studies reviewed. The authors concluded that more and better research is needed to draw robust conclusions about how care settings influence outcomes and costs of LTC for older adults.

## Methods

We used a deliberative process to identify specific research needs and research design considerations. First, we refined and developed a list of evidence gaps from the comparative effectiveness review (CER). Second, we recruited a diverse panel of stakeholders who represented a variety of perspectives relevant to the topic. We sought research representatives who were national experts familiar with evidence-based research and aware of the obstacles faced in conducting well-designed research in health services. We invited representatives from organizations supporting or conducting relevant research and/or programs including the U.S. Department of Health and Human Services Office of the Assistant Secretary for Planning and Evaluation, the Visiting Nurse Service of New York, LeadingAge, and others, as well as policy and payer representation from the U.S. Centers for Medicare & Medicaid Services (CMS). We engaged consumer and provider groups, including AARP and the National Center for Assisted Living, because the decisional dilemmas faced by these groups are critical to identifying and prioritizing research questions. Many stakeholders were also involved in the CER process as Key Informants, technical expert panel members, or peer reviewers. A total of 13 stakeholders across these groups responded to our invitation and expressed an interest in participating in this project.

We then held conference calls with stakeholders to refine the research gaps identified in the CER. We revised the preliminary research gaps based on our stakeholder discussions and phrased the identified gaps as research questions.

Many stakeholders raised the important question of whether research should continue to compare the relative effectiveness of HCBS and NH care given the changes in social thinking that have occurred and the preference in most cases for HCBS. Based on the stakeholder feedback, we grouped research questions into two major sets that we further divided into methodological questions and topical questions. The first set addressed the narrow issue that was the topic of the CER—the comparison of LTC delivered through HCBS and in NHs. The second set addressed broader LTC issues that stakeholders (and reviewers from the CER) raised as salient for the current policy environment. The second set did not frame research questions as a comparison of HCBS and NHs, but rather, treated these settings and services separately.

We sent the two sets of research questions to stakeholders and asked them to rank the questions by priority. For the first set of research questions addressing the comparison of HCBS with NHs, stakeholders numerically ranked their top three of seven methodological research questions, and their top one of three topical research questions. For the second set of broader research questions on LTC for older adults, stakeholders numerically ranked their top 4 of 11 methodological research questions, and their top 5 of 12 topical research questions. We calculated unweighted and weighted scores based on their rankings. We identified breakpoints in the weighted rankings that separated high- and moderate-/low-priority research questions. Highly prioritized research questions were considered research needs. We discussed research design considerations for research needs.

## Results

Of 13 invited stakeholders, 10 completed the ranking exercise.

### Methodological Research Needs

Among the methodological questions for the comparison of LTC delivered through HCBS and in NHs, the number one priority was the identification of standardized outcome measures for HCBS and NH recipients. Eight of 10 stakeholders ranked this as a priority. For the broader set of methodological questions about LTC through HCBS and in NHs, the most highly ranked were four questions related to outcome measures and descriptions of the interventions.

- What standardized outcome measures should be used for HCBS and NH recipients that fully measure benefits and harms and are capable of showing meaningful change?
- What should be included in a taxonomy of HCBS, and how do we measure a “service” to enable research across different types of HCBS?
- What is the minimum set of potential outcomes for HCBS and NH recipients? For example, outcomes may include abuse, loneliness (as an intermediate outcome that could predict institutionalization), and transitions (likelihood of being discharged from a NH after an individual enters a NH, likelihood of going back to a NH after discharge from the NH, and likelihood of being rehospitalized after experiencing a hospitalization).
- What quality-of-life measures and disease-specific measures should be used to capture an individual's experience in LTC?
- What should be included in a taxonomy for assisted living to assess the effectiveness of services and to compare to other HCBS?

Addressing methodological research needs will enhance the utility of future research on LTC for older adults. The methodological research needs identified by stakeholders as the highest priorities pertain to the outcome measures that are appropriate within these care settings and important to care recipients and to the definition of services that individuals receive.

The CER highlighted that comparing results was difficult because studies used different outcome measures and methods of data collection. The differences in care environments, including which measurements are used and who collects the data, may impact results. These differences can make it challenging to determine whether different effects across different studies are due to outcome measurement issues or other issues. Stakeholders also indicated that finding standardized outcome measures is an important priority. Additionally, the CER and stakeholders stressed the importance of examining outcomes that measure an individual's experience across multiple domains, including outcomes that are most important to individuals when they choose between care settings. There was insufficient evidence for most outcomes examined in the CER, including outcomes related to quality of life and experience of care. Consensus on outcome measures would improve future research and the ability to understand how different types of LTC affect outcomes of older adults.

The CER emphasized that most studies did not sufficiently describe the settings and services received, and few studies specified the type, frequency, or intensity of services. The nature of HCBS and AL services can vary widely, so a description of services is necessary to judge applicability. Our discussions with stakeholders, and the results of the ranking process, indicate that creating and using a standardized taxonomy for HCBS and AL is important to understanding research on these types of care. CMS has been working with contractors to produce a taxonomy of services (www.nasuad.org/documentation/hcbs2011/Presentations/W10RegencyA.pdf). Using this taxonomy in future research will increase the usefulness and comparability of research efforts.

### Topical Research Needs

The highest priority ranked among the topical gaps for the comparison of LTC delivered through HCBS and in NHs related to the pattern of transitions and the factors leading to transitions for LTC users. We also identified four high-priority topical questions to address for LTC delivered through HCBS and in NHs. All topical research needs primarily addressed populations and interventions.

- What is the pattern of transitions of LTC users? What factors lead to transitions?
- What works for whom? How does HCBS affect different subpopulations/subgroups?
- How do outcomes of individuals in managed care programs differ from those of individuals in fee-for-service programs? Do managed LTC programs for dual eligibles offload costs onto Medicare?
- What services within HCBS result in better outcomes for individuals?
- How do policies, payment rates, and availability of services in different areas impact who does or does not receive HCBS?

LTC users commonly transition through different settings as needs and preferences change, but evidence from the CER suggests that these transitions are rarely characterized or modeled in studies. Studies infrequently follow individuals as they move in and out of different settings, and they are often not explicit about individuals' transitions over time or factors that led to transitions. Stakeholders indicated that understanding LTC users' transitions would help us develop interventions to avoid or improve transitions.

No studies evaluated in the CER addressed outcomes for subgroups. Stakeholders rated the understanding of the efficacy of different interventions for different subgroups as an important priority. Subgroups might be defined by characteristics such as race/ethnicity, socioeconomic status, and diagnoses. In our discussions, many stakeholders indicated the need to better understand managed LTC programs, including how outcomes and costs compare for managed LTC users compared to fee-for-service users. From a policy and payer perspective, this resonated as a particularly salient research question.

Stakeholders were particularly interested in understanding how different services within the package of HCBS improve outcome trajectories for individuals. They were also interested in how the policy and payment environment affects HCBS and NH use. These topics were rated as high priorities to address in future research.

### Considerations for Potential Research Design

Randomization can increase the likelihood that HCBS and NH populations are comparable on measured as well as unmeasured factors. However, randomization to HCBS versus NH or to AL versus NH is generally precluded for practical and ethical reasons. Those with a strong preference for community care would be unlikely to accept a NH placement, and many individuals who believe they need NH care have already decided to enter a NH.

While RCTs are not likely to be used for the HCBS versus NH comparison, stakeholders suggested that RCTs could be used to compare the effects of variations of HCBS. Randomization would allow for more robust research about the efficacy of different type of services within HCBS and about the efficacy of HCBS for different subgroups.

RCTs are expensive and difficult to implement, and therefore unlikely to be widely used in this topic area. Moreover, there is likely to be a strong sampling bias in who agrees to be randomized, raising questions about applicability. Cohort studies are less resource intensive and produce applicable results. Longitudinal cohort studies follow individuals over a period of time and would be practical to examine the outcome trajectories of LTC users. Large sample sizes will be necessary to allow for subgroup and interaction analyses, but this is easier to attain in cohort studies than in RCTs.

Prospective cohort studies enroll and follow patients over time to assess outcomes. Because individuals within an LTC setting are at different points on an outcome trajectory, it can be difficult to understand how interventions may modify the trajectory. Using an LTC admission cohort with a prospective cohort design would allow researchers to follow individuals along their entire trajectory for a defined period of time. This type of design would indicate how the intervention does or does not modify outcomes over time. The ability of this design to assess differences can be improved by using consistent measures and observation schedules and by ensuring data is collected by independent observers.

Like RCTs, cohort studies can be costly and there can be issues with attrition as individuals are lost over time. The lack of randomization may also create potential selection bias. Therefore, studies need to use statistical techniques to adjust for selection to ensure that the comparisons between groups are unbiased. These techniques include multivariate analysis, propensity scores, instrumental variables, and frontier analysis.2 Frontier analysis identifies groups with specific clusters of key patient characteristics that pertain to a specific health issue. Factors considered for adjustment should include LTC attitudes held by both clinicians and consumers and availability of informal support. Studies should adjust for case mix and account for changes in the composition of the populations that result from deaths or transfers to different settings.

In discussions with stakeholders, other research design considerations that were mentioned included the need for studies with more generalizable samples and populations of private pay LTC users.

## Discussion

This FRN project refined and prioritized research needs relevant to the Key Questions addressed in the CER “Long-Term Care for Older Adults: A Review of Home and Community-Based Services Versus Institutional Care.” We refined and developed a list of evidence gaps from the CER, including methodological gaps that limited the utility of the current research and topical gaps that limited conclusions about efficacy and comparative effectiveness of LTC for older adults delivered through HCBS and in NHs. We used a deliberative process to refine and expand our set of research gaps through conversations with stakeholders who represented diverse perspectives of expertise on the topic. Our stakeholder group included researchers, research and funding organizations, payers, providers, and consumer groups. Some stakeholders offered two or more perspectives. We revised the preliminary research gaps based upon these discussions and phrased the identified gaps as research questions.

Our stakeholder group raised an important question early: given the changes in social thinking about the relative roles of institutional care and HCBS, should further research continue to address relative effectiveness or should it assume that HCBS is preferable in most situations? Based on the stakeholder feedback, we grouped research questions into two major sets, each of which was further subdivided into methodological questions and topical questions. The first set addressed the narrow issue that was the topic of the CER—the comparison of LTC delivered through HCBS and in NHs. The second set addressed broader LTC issues that stakeholders raised as salient for the current policy environment. Stakeholders then ranked research questions, and the most highly ranked questions were deemed research needs.

Addressing methodological research needs will enhance the utility of future research on LTC for older adults. A standardized set of patient-centered outcomes, with guidance on interpreting changes in outcomes, will provide researchers with an approach to determine the effectiveness of various types of LTC. The quality of the evidence will also be enhanced if researchers use a standardized definition of LTC services. Following consensus on these issues, more comparable studies on LTC for older adults should become available.

Topical research priorities reflected the need to better understand which interventions are effective for which populations. Identifying how subpopulations are affected by different interventions and which services are most effective will help consumers and policymakers choose better modes of care. Characterizing LTC users' transitions will improve research about the most effective type and timing of interventions.

Future studies on LTC for older adults should aim to reduce bias as much as possible, using research design and statistical techniques. Larger sample sizes will allow more research on subpopulations, and longer followup times will allow a better understanding of how interventions may modify outcomes over time.

It should be noted that the prioritized research needs reflect the opinions of these stakeholders and may not be generalizable to the population of stakeholders on this topic.

## Conclusions

We identified specific research needs that should be useful in future efforts to address the effectiveness of LTC for older adults delivered through HCBS and in NHs. The clinical and policy context of LTC is changing. Comparative effectiveness may be less salient than understanding what makes such care effective in the first place for various client groups. Therefore, we reported research needs related to the comparison of HCBS and NH care that was the focus of the CER, and we also reported research needs from the broader set of questions that stakeholders felt were more important priorities in the current policy environment. Future research in this area will create a broader and stronger evidence base for making care and policy decisions:

- What standardized outcome measures should be used for HCBS and NH recipients that fully measure benefits and harms and are capable of showing meaningful change?
- What should be included in a taxonomy of HCBS and how do we measure a “service” to enable research across different types of HCBS?
- What is the minimum set of potential outcomes for HCBS and NH recipients? For example, outcomes may include abuse, loneliness as an intermediate outcome that could predict institutionalization, transitions (likelihood of being discharged from a NH after an individual enters an NH, likelihood of going back to an NH after discharge from the NH, and likelihood of being rehospitalized after experiencing a hospitalization).
- What quality-of-life measures and disease specific measures should be used to capture an individual's experience in LTC?
- What should be included in a taxonomy for assisted living to assess the effectiveness of services and to compare to other HCBS?
- What is the pattern of transitions of LTC users? What factors lead to transitions?
- What works for whom? How does HCBS affect different subpopulations/subgroups?
- How do outcomes of individuals in managed care programs differ from those of individuals in fee-for-service programs? Do managed LTC programs for dual eligibles offload costs onto Medicare?
- What services within HCBS result in better outcomes for individuals?
- How do policies, payment rates, and availability of services in different areas impact who does or does not receive HCBS?

## Glossary

AL: Assisted living
CER: Comparative Effectiveness Review
CMS: Centers for Medicare & Medicaid Services
FRN: Future research needs
HCBS: Home and community-based services
LTC: Long-term care
NH: Nursing home
RCT: Randomized controlled trial

## References

1 Feder J, Komisar HL, Niefeld M. Long-term care in the United States: an overview. Health Affairs. 2000;19(3):40-56. [pmid: 10812780].
2 Johnson PE, Veazie PJ, Kochevar L, et al. Understanding variation in chronic disease outcomes. Health Care Manag Sci. Aug. 2002;5(3):175-89. [pmid: 12363045].