# Discussion

This FRN project refined and prioritized research needs relevant to the Key Questions addressed in the CER “Long-Term Care for Older Adults: A Review of Home and Community-Based Services Versus Institutional Care.” We refined and developed a list of evidence gaps from the CER, including methodological gaps that limited the utility of the current research and topical gaps that limited conclusions about efficacy and comparative effectiveness of LTC for older adults delivered through HCBS and in NHs. We used a deliberative process to refine and expand our set of research gaps through conversations with stakeholders who represented diverse perspectives of expertise on the topic. Our stakeholder group included researchers, research and funding organizations, payers, and providers and consumer groups. Some stakeholders offered two or more perspectives. We revised the preliminary research gaps based upon these discussions and phrased the identified gaps as research questions.

Our stakeholder group raised an important question early: given the changes in social thinking about the relative roles of institutional care and HCBS, should further research continue to address relative effectiveness or should it assume that HCBS is preferable in most situations? Based on the stakeholder feedback, we grouped research questions into two major sets, each of which was further subdivided into methodological questions and topical questions. The first set addressed the narrow issue that was the topic of the CER—the comparison of LTC delivered through HCBS and in NHs. The second set addressed broader LTC issues that stakeholders raised as salient for the current policy environment. Stakeholders ranked the questions by priority, and the most highly ranked questions were deemed research needs. We included ranking results from both sets of questions.

Addressing methodological research needs will enhance the utility of future research on LTC for older adults. A standardized set of patient-centered outcomes, with guidance on interpreting changes in outcomes, will provide researchers with an approach to determine the effectiveness of various types of LTC. The quality of the evidence will also be enhanced if researchers use a standardized definition of LTC services. Following consensus on these issues, more comparable studies on LTC for older adults should become available.

Topical research priorities reflected the need to better understand which interventions are effective for which populations. Identifying how subpopulations are affected by different interventions and which services are most effective will help consumers and policymakers choose better modes of care. Characterizing LTC users' transitions will improve research about the type and timing of interventions that may prove most effective.

Future studies on LTC for older adults should aim to reduce bias as much as possible, using research design and statistical techniques. Larger sample sizes will allow more research on subpopulations, and longer followup times will allow a better understanding of how interventions may modify outcomes over time.

This FRN project benefited from the perspectives brought by broad panel of stakeholders. However, our inability to collect a representative perspective from a larger sample of stakeholders is also a limitation. The prioritized research needs reflect the opinions of these stakeholders and may not be generalizable to the population of stakeholders on this topic. The sample size was limited by standards and guidelines for statistical surveys administered by the Office of Management and Budget requiring compliance with the Paperwork Reduction Act and Information Collections Policy (44 USC 3501-3520). The Act was designed to minimize the paperwork burden on the public, assure that high quality data are obtained, and minimize costs. However, the approval process to allow more than nine nongovernment participants exceeded the length of time available to complete this project.