# Minnesota EPC Long-Term Care for Older Adults Research Needs Stakeholder Meeting Agenda

Conference Call Goal: Final list of topics to advance to the rating process

1. Ground rules for phone call:
  a. In the interest of time, conduct roll call rather than introductions
  b. To aid with identification, please preface all comments with your name
2. Roll Call
3. Brief overview of meeting purpose and agenda
  a. Description of the forthcoming AHRQ report (see LTC Review Draft Executive Summary attachment)
  b. Outline scope/methods for the current project
4. Presentation of identified gaps (LTC Research Knowledge Gaps attachment)
  a. Cross-cutting themes identified in report.
    i. Methodological issues
    ii. Topical issues
  b. Specific research questions addressed – the right questions?
5. Discussion of research gaps: what to add, what to remove
6. Discussion of the AHRQ LTC Selection Criteria for New Research attachment
7. Overview of web-based prioritization process
8. Outline of next steps.
  a. Call summary emailed to stakeholders.
  b. Comments to summary (if any) due from stakeholders within 5 working days
  c. Minnesota EPC will circulate revised gaps list for prioritization
  d. Stakeholders prioritization responses due within 5 working days