# Minnesota Evidence-based Practice Center (MN EPC) Long-Term Care for Older Adults Research Needs Project: Stakeholder Conference Call Information

This memo outlines specific areas where your expert feedback is requested for this AHRQ-funded project. The attached information forms the basis of your upcoming conference call with us, so please review it prior to our call. We are specifically interested in any additions, modifications, or deletions to the list of research knowledge gaps that you would suggest, especially if you believe that the list does not include pressing research issues that hinder the field's ability to address questions about long-term care for older adults delivered through home and community-based services versus care provided in institutional settings such as nursing homes adequately.

Background: The forthcoming MN EPC report, Long-Term Care for Older Adults: A Review of Home and Community-Based Services Versus Institutional Care, is currently being finalized. It focuses on two key questions related to the benefits/harms and costs of long-term care for older adults, summarizing the literature on this topic from 1995 through 2012. The key questions are listed on page 2 of this document. Broadly, the review compared the characteristics of the populations of older adults using home and community-based services and nursing homes, as well as the benefits, harms, and costs for these individuals. The outcomes examined included physical, cognitive, and mental health outcomes, mortality, adverse effects, utilization, and costs. The review found the existing literature to be sparse and of low to moderate quality, so no strong conclusions could be made regarding any outcome examined. A number of recommendations were made for further research within the report.

This project will expand and build on those recommendations to provide further specification and focus for future research endeavors. The draft report recommendations are listed in the LTC Research Knowledge Gaps document.

Project objective: The goal of this project is to use expert/stakeholder feedback to identify and prioritize the current research knowledge gaps on long-term care for older adults, and recommend the optimal research approaches to best fill those knowledge gaps to improve outcomes of older adults receiving long-term care.

What we need from you during the conference call: Please review the attached document, LTC Research Knowledge Gaps. The document summarizes the knowledge gaps identified in the forthcoming report. During the call we will discuss:

- What gaps you feel should be added or clarified.
- Which gaps should be excluded from the list due to not meeting a minimum importance threshold.
- If there are any ongoing or recently completed studies that we should be aware of.

Timeline and Plan: A summary of the conference call will be emailed to stakeholders within one week, where you will be given the opportunity to provide any additional comments or clarification. After comments are received, the MN EPC will draft a final list of research gaps. Stakeholders will then engage in a ranking procedure of research priorities using a web-based prioritization software through which a suggested prioritization list will be generated. A final report will be generated by the MN EPC in July, which will later be posted on AHRQ's Effective Health Care web site.

We thank you for your participation in this AHRQ-sponsored project, and look forward to working with you. If you have any questions, please feel free to contact Robert Kane at kanex001@umn.edu or Andrea Wysocki at wyso0014@umn.edu.

## Long-Term Care for Older Adults: A Review of Home and Community-based Services Versus Institutional Care

The following key questions (KQ) were investigated in the review for adults age 60 and older:

Key Question 1: What are the benefits and harms of LTC provided through HCBS compared to institutions such as NH for older adults, aged 60 and older, who need LTC?

a. To what extent do HCBS and NHs serve similar populations?
b. How do the outcomes of the services differ when tested on similar populations?
c. What are the harms to older adults as a result of HCBS and NHs?
  Reported harms include safety, inadequate preventative care, unnecessary hospitalizations, and concerns about abuse or neglect.

Key Question 2: What are the costs (at the societal and personal levels) of HCBS and NHs (per recipient and in the aggregate) for adults age 60 and older? Costs may include direct costs of care as well as resource utilization and family burden.

Direct costs of care refer to the LTC costs of HCBS recipients and NH residents. Resource use includes the costs of acute care services such as physician and hospital care as well as the costs of other subsidies or transfer programs. Family burden includes both the out-of-pocket and opportunity costs of care.