# Selection Criteria for New Research: Long-Term Care for Older Adults Research Needs

Current importance: Includes considerations such as uncertainty for decisionmakers, benefits and harms for individual LTC recipients, and high costs

- Represents a significant disease burden; large proportion or priority population
- Is of high public interest; affects healthcare decision-making, outcomes, or costs for a large proportion of the US population or for a priority population in particular
- Represents important uncertainty for decision-makers
- Incorporates issues around both benefits and potential harms
- Represents important variation in care, or controversy in what constitutes appropriate care
- Represents high costs due to common use, to high unit costs, or to high associated costs to consumers, to patients, to healthcare systems, or to payers

Potential impact: Includes the likelihood the study will inform practice and policy, whether the research addresses inequities, vulnerable and diverse populations, or ethical, legal, and social issues pertaining to the form of LTC delivery

- Potential for significant health impact
  ○ To improve health outcomes
  ○ To reduce significant variation related to quality of care
  ○ To reduce unnecessary burden on those with health care problems
- Potential for significant economic impact, reducing unnecessary or excessive costs
- Potential for change
  ○ The proposed topic exists within a clinical, consumer, or policy-making context that is amenable to evidence-based change
- Potential risk from inaction
  ○ Lack of evidence for decision-making produces unintended harms
- Addresses inequities, vulnerable populations, patient subgroups with differential impact

Incremental value: Includes considerations of the potential for new knowledge

- Adds useful new information to existing portfolio of research on topic or validates existing research where a body of evidence is scant

Feasibility: Includes factors related to anticipated research designs, such as generalizable samples, measurement of study variables from various data sources, and unobserved variables that may create a risk of bias

- Interest among researchers
- Duration
- Cost
- Methodological complexity
- Implementation difficulty
- Facilitating factors
- Potential funders

(Modified for primary research from: Whitlock EP, et al. AHRQ Series Paper 3: Identifying, selecting, and refining topics for comparative effectiveness systematic reviews: AHRQ and the Effective Health-Care program. Journal of Clinical Epidemiology. 2010;63:491-501. [pmid: 19540721]. )