# Abbreviations

AL: Assisted living
CER: Comparative effectiveness review
CMS: Centers for Medicare & Medicaid Services
FRN: Future research needs
HCBS: Home and community-based services
LTC: Long-term care
NH: Nursing home
PACE: Program of All-Inclusive Care for the Elderly
PICOTS: Population, intervention, comparison, outcome, timing, setting
RCT: Randomized controlled trial