# Results

We had six stakeholders participate in the first round, six stakeholders participate in the second round, six stakeholders participate in the third round, and five stakeholders participate in the fourth round.

## Research Needs

We describe below how our stakeholders prioritized future research needs within the PICOTS framework by each element. We have created a conceptual framework for studies to address future research needs in the field of adult weight gain prevention (Figure 1).

Figure 1 Framework for future research on strategies for the prevention of adult weight gain to address high-priority evidence gaps

Note: BMI = body mass index

Figure 1 illustrates the analytic framework for identification of potential research gaps. The framework identifies possible gaps in the research that has been done in strategies to prevent weight gain in adults. The figure includes a list of gaps regarding strategies to prevent weight gain in adults.

Populations. In round 1, our stakeholders reached majority consensus that the following four populations were of highest priority: all adults, young adults, normal-weight adults, and overweight adults (Table 4). Stakeholders gave the most votes to the young adult population. They commented that they made this decision given the potential for the continuation of healthy habits established in youth throughout the life course. Stakeholders commented that they selected all adults because they wanted to include the broadest possible audience for weight gain prevention in order to have the greatest impact on the obesity epidemic. Normal-weight and overweight adults were selected given that weight gain prevention would prevent the development of obesity and its associated comorbid conditions. In addition to identifying these broad populations, stakeholders also prioritized several subgroups at high risk for obesity by assigning them scores in Delphi round 2. We considered subgroups that received the lowest average rankings as highest priority. Stakeholders ranked racial/ethnic minorities (1.8) and adults with cardiovascular disease or diabetes (1.8) as these high-priority subgroups for future research. Obese adults (2.7), adults with cancer (3.8), and adults with severe mental illness (4.8) received the highest average scores, which indicated that stakeholders felt they were of lower priority.

Table 4 Stakeholder priority ratings for population gaps for future research in strategies to prevent weight gain in adults

Population Groups | Round 1 Votes for High-Priority Populations (N=6) | Round 2 Scores (N=6)
Young adults (18–35) | 5^*^ | ‡
All adults | 4^*^ | ‡
Overweight | 3^*^ | ‡
Normal weight | 3^*^ | ‡
Middle aged (36-64) | 2 | ‡
Low income | 2 | ‡
Other | 2 | ‡
Older (65+) | 1 | ‡
Racial/ethnic minorities | 1 | 1.8^*^
Obese | 1 | 2.7
Cardiovascular disease or diabetes | 0 | 1.8^*^
Severe mental illness | 0 | 4.8
Cancer | 0 | 3.8
Women | 0 | ‡
Men | 0 | ‡

Notes:

* Indicates prioritized research need from round 1.

‡ Indicates option not included for prioritization in round 2.

N = number of stakeholders who participated.

Interventions/strategies. In round 1, our stakeholders reached majority consensus that a combination of interventions is the highest priority for future research (Table 5). They felt that no single strategy alone was likely to be effective, and therefore, only a combination of approaches should be employed in the future. The majority of stakeholders identified medications as the lowest priority strategies for weight gain prevention research (Table 6). Stakeholders commented that they ranked medications lower due to concerns about the long-term viability of such an approach and the potential for side effects.

Table 5 Stakeholder rating for the highest and lowest priority strategy gaps for future research in strategies to prevent weight gain in adults

Strategies | Round 1 Votes for High- Priority Strategy (N=6) | Round 1 Votes for Low- Priority Strategy (N=6)
Combination of interventions | 4^*^ | 1
Other | 2 | N/A
Policy | 2 | 1
Self-management | 2 | 0
Diet | 1 | 0
Physical activity | 1 | 0
Medications | 0 | 4

Notes:

* Indicates prioritized research need.

N = number of stakeholders who participated.

Table 6 Stakeholder rating for the highest and lowest priority combination strategy gaps for future research in strategies to prevent weight gain in adults

Combination | Round 2 Votes for High-Priority Combination Strategy (N=6) | Round 2 Votes for Low-Priority Combination Strategy (N=6)
Self-management AND diet AND physical activity | 4^*^ | 0
Self-management AND diet AND physical activity AND environmental change | 3 | 1
Self-management AND environmental change | 2 | 1
Self-management AND diet | 1 | 2
Self-management AND diet AND environmental change | 1 | 0
Self-management AND physical activity AND environmental change | 1 | 1
Self-management AND physical activity | 0 | 1

Notes:

* Indicates prioritized research need.

N = number of stakeholders who participated.

Stakeholders reached majority consensus that combination interventions should combine the following elements: (1) self-management + diet + physical activity, or (2) self-management + diet + physical activity + environment (Table 6). No consensus majority was reached about the lowest priority combination of interventions (Table 6).

In Delphi round 3, stakeholders also identified what components should comprise diet and physical activity interventions. Stakeholders felt that diet interventions should combine counseling with specific dietary recommendations regarding calorie intake or dietary composition and a diet-related self-management strategy such as meal planning or calorie tracking (Table 7). Stakeholders did not reach consensus on the type of counseling, dietary recommendation, or self-management strategy of greatest priority. Similarly, stakeholders felt that physical activity interventions should combine counseling with an exercise plan that combines aerobic exercise, resistance training, and stretching and an exercise-related self-management strategy such as exercise tracking (Table 8). Stakeholders did not reach consensus on the type of counseling, exercise plan, or self-management strategy of greatest priority. All stakeholders felt that printed materials were unlikely to change behavior, and therefore, should not be a prioritized strategy in future research.

Table 7 Highest priority components of dietary interventions

Dietary Plan | Round 3 Votes (N=6) | Modality of Intervention Delivery | Round 3 Votes (N=6) | Targeted Behavior | Round 3 Votes (N=6)
Dietary composition | 4 | Group | 5 | Meal planning | 5
Calorie restriction | 3 | Individual | 4 | Calorie tracking | 2
Both | 5 | Telephone/Web | 3 | Both | 5
None | 0 | Education session | 0 | None | 0
| | Printed materials | 0

Abbreviation: N = number of stakeholders who participated.

Table 8 Highest priority components of physical activity interventions

Exercise Plan | Round 3 Votes (N=6) | Modality of Intervention Delivery | Round 3 Votes (N=6) | Targeted Behavior | Round 3 Votes (N=6)
Aerobic exercise | 3 | Group | 4 | Pedometer | 2
Resistance training | 0 | Individual | 6 | Exercise tracking | 8
Stretching | 0 | Telephone/Web | 2 | Both | 2
Aerobic + resistance | 3 | Education session | 0 | None | 0
Aerobic + stretching | 2 | Printed materials | 0
Resistance + stretching | 0
Aerobic + resistance + stretching | 4

Abbreviation: N = number of stakeholders who participated.

Comparisons. Our stakeholders reached majority consensus that several head-to-head comparisons of interventions would be a high priority for future research. These high priority comparisons include: (1) self-management + diet VERSUS self-management + physical activity, or (2) self-management + diet VERSUS self-management + diet + physical activity (Table 9).

Table 9 Stakeholder rating for the highest priority comparison strategy gaps for future research in strategies to prevent weight gain in adults

Arm 1 | Arm 2 | Round 2 Votes (N=6)
Self-management AND diet AND physical activity | Self-management AND diet | 4^*^
Self-management AND diet AND physical activity | Self-management AND diet AND environmental change | 3
Self-management AND diet AND physical activity | Self-management AND physical activity | 2
Self-management AND diet AND physical activity | Self-management AND diet AND physical activity AND environmental change | 2
Self-management AND diet AND physical activity | Self-management AND environmental change | 2
Self-management AND diet AND physical activity | Self-management AND physical activity AND environmental change | 1
Self-management AND diet | Self-management AND physical activity | 5^*^
Self-management AND diet | Self-management AND diet AND environmental change | 3
Self-management AND diet | Self-management AND environmental change | 2
Self-management AND diet | Self-management AND diet AND physical activity AND environmental change | 1
Self-management AND physical activity | Self-management AND physical activity AND environmental change | 3
Self-management AND physical activity | Self-management AND environmental change | 1
Self-management AND physical activity AND environmental change | Self-management AND diet AND physical activity AND environmental change | 1

Notes:

* Indicates prioritized research need.

N = number of stakeholders who participated.

Outcomes. We felt that weight and body mass index were logical and well-established outcomes for the weight gain prevention field. Our stakeholders instead evaluated secondary outcomes. Our stakeholders reached majority consensus that two secondary outcomes should be assessed in future trials: weight-related clinical outcomes and adherence to the intervention (Table 10). Weight-related clinical outcomes may include conditions such as hypertension, diabetes mellitus, and dyslipidemia. Stakeholders felt that assessing adherence would help determine the efficacy and effectiveness of the intervention, and that understanding whether preventing weight gain improves clinical outcomes would justify investment in implementing such programs on a large scale. The majority of stakeholders identified skinfold thickness as the lowest priority secondary outcome (Table 10). Skinfold thickness was rated lower due to lack of association with health outcomes and the existence of other metrics that are easier to measure or provide better estimates of adiposity.

Table 10 Stakeholder rating for the highest and lowest priority secondary outcome gaps for future research in strategies to prevent weight gain in adults

Secondary Outcomes | Round 1 Votes for High-Priority Secondary Outcomes (N=6) | Round 1 Votes for Low-Priority Secondary Outcomes (N=6)
Weight-related clinical outcomes | 4^*^ | 0
Adherence | 3^*^ | 0
Mortality | 2 | 2
Waist circumference | 1 | 0
Body fat % | 1 | 0
Other | 1 | 0
Skinfold thickness | 0 | 4
Adverse effects | 0 | 0

Notes:

* Indicates prioritized research need.

N = number of stakeholders who participated.

Settings. In round 1, our stakeholders reached majority consensus regarding three high-priority settings, which included the workplace, the community, and the home (Table 11). Stakeholders were motivated to select these settings, because they felt that work, home, and community-based interventions would likely have the greatest impact on preventing weight gain and obesity. They noted that adults spend the majority of their time in one of these settings, and that other people in these settings are likely to have a strong influence on their behavior. The majority of stakeholders identified clinic-based weight gain prevention programs as the lowest priority for future research (Table 11). They rated clinic-based interventions low due to concerns of whether physicians and health care providers have time and adequate training to perform such tasks.

Table 11 Stakeholder ratings for the highest and lowest priority setting gaps for future research in strategies to prevent weight gain in adults

Settings | Round 1 Votes for High-Priority Settings (N=6) | Round 1 Votes for Low-Priority Settings (N=6)
Home | 4^*^ | 1
Work | 4^*^ | 0
Community | 4^*^ | 0
Clinic | 0 | 4
College | 0 | 1
Other | 0 | N/A

Notes:

* Indicates prioritized research need.

N = number of stakeholders who participated.

## Research Questions

Based upon the results of the research needs, we created a matrix of possible research questions (N=16). In Delphi round 3, our stakeholders reached majority consensus regarding seven research questions as the highest priorities for future research from the matrix of possible questions. These seven questions are listed in Table 12. In round 4, stakeholders assigned a score of 1 to 5 to each question, where 5 means that the question is very likely to provide valuable and impactful results and 1 that it is less likely to provide valuable and impactful results. The mean score for each question is presented in Table 12.

Table 12 Stakeholder rating for the value in addressing each research question to prevent weight gain in adults on a 1-5 scale, in which 1 is the lowest value and 5 is the highest value

Research Questions Prioritized in Round 3 | Round 4 Mean Impact Scores (N=5)
To prevent weight gain in ALL adults, what is the comparative effectiveness of adding PHYSICAL ACTIVITY versus NOT adding physical activity to a WORK-based self-management and diet intervention? | 4.0
To prevent weight gain in ALL adults, what is the comparative effectiveness of adding PHYSICAL ACTIVITY versus NOT adding physical activity to a HOME-based self-management and diet intervention? | 3.8
To prevent weight gain in ALL adults, what is the effectiveness of a WORK-based self-management and PHYSICAL ACTIVITY intervention versus a self-management and DIET intervention? | 3.8
To prevent weight gain in ALL adults, what is the effectiveness of a HOME-based self-management and PHYSICAL ACTIVITY intervention compared with a self-management and DIET intervention? | 3.8
To prevent weight gain in OVERWEIGHT adults, what is the comparative effectiveness of adding PHYSICAL ACTIVITY versus NOTadding physical activity to a HOME-based self-management and diet intervention? | 3.4
To prevent weight gain in OVERWEIGHT adults, what is the effectiveness of a HOME-based self-management and PHYSICAL ACTIVITY intervention compared with a self-management and DIET intervention? | 3.4
To prevent weight gain in YOUNG adults, what is the comparative effectiveness of adding PHYSICAL ACTIVITY versus NOT adding physical activity to a HOME-based self-management and diet intervention? | 3.4

Abbreviation: N = number of stakeholders who participated.

All stakeholders agreed that the field of weight gain prevention research would benefit from a standardized definition of weight maintenance (Table 13). The stakeholders felt that the definition should include standards for maintenance of both weight and BMI. One stakeholder commented that this standard should be clinically meaningful.

Table 13 Methodological question for future research

| What is a clinically meaningful definition of weight maintenance among adults, expressed as both weight (kg) and body mass index (kg/m^2^),that can be used as the standard across studies of weight gain prevention?

## Study Design Considerations

After the report's authors reviewed the research questions prioritized by our stakeholders, they suggested that randomized controlled trials (RCTs) may be the most appropriate study design to answer these questions. They felt that the advantage of the RCT is the lack of confounding and selection bias; however, they stipulated that a well-conducted RCT should assess outcomes by individuals blinded to treatment assignment, assess adherence to the intervention, and maintain adequate followup of enrolled patients. The report authors recognized that such RCTs would be costly.

Stakeholders also identified improvements in study design, methods, and reporting that they would recommend be employed by future studies. In Table 14, we present the study design, methods, and reporting elements that at least 50 percent of our stakeholders agreed should be used in future studies.

Table 14 Stakeholder rating for the highest priority methodological needs for future research in strategies to prevent weight gain in adults

Methods | Round 1 Votes (N=6)
Describe randomization process | 6
Recruit adequate sample size to power | 6
Adjust for confounding in observational studies | 5
Report non-statistically significant results | 5
Report measures of variance | 4
Mask outcome assessors to study group assignment | 3
Minimize or account for losses to followup | 3
Other | 0

Abbreviation: N = number of stakeholders who participated.

## Identification of Ongoing Studies

We identified 3,027 titles in clinicaltrials.gov, of which 727 were identified as potentially eligible during title review. During full review, we identified 51 studies currently recruiting or ongoing that may address at least one of the Key Questions from the original report. We also identified 35 recently completed studies that may address at least one of the Key Questions; however, results were not yet available from these studies. These 86 ongoing or recently completed studies are listed in Appendix Table 2.