# References

1 Flegal KM, Carroll MD, Kit BK, et al. Prevalence of obesity and trends in the distribution of body mass index among US adults, 1999-2012. JAMA. 2012;307:491-7. [pmid: 22253363].
2 Flegal KM, Graubard BI, Williamson DF, et al. Cause-specific excess deaths associated with underweight, overweight and obesity. JAMA. 2007;298(17):2028-37. [pmid: 17986696].
3 Fontaine KR, Redden DT, Wang C, et al. Years of life lost due to obesity. JAMA. 2003;289(2):187-93. [pmid: 12517229].
4 Tsai AG, Williamson DF, Glick HA. Direct medical cost of overweight and obesity in the USA: a quantitative systematic review. Obes Rev. 2011;12(1):50-61. [pmid: 20059703].
5 U.S. Department of Health and Human Services. Healthy People 2020. www.healthypeople.gov/2020/default.aspx. Accessed September 2, 2012.
6 Anderson LM, Quinn TA, Glanz K, et al. The effectiveness of worksite nutrition and physical activity interventions for controlling employee overweight and obesity: a systematic review. Am J Prev Med. 2009;37(4):340-57. [pmid: 19765507].
7 Loveman E, Frampton GK, Shepherd J, et al. The clinical effectiveness and cost-effectiveness of long-term weight management schemes for adults: a systematic review. Health Technol Assess. 2011;15(2):1-182. [pmid: 21247515].
8 Lemmens VE, Oenema A, Klepp KI, et al. A systematic review of the evidence regarding efficacy of obesity prevention interventions among adults. Obes Rev. 2008;9(5):446-55. [pmid: 18298429].
9 Lombard CB, Deeks AA, Teede HJ. A systematic review of interventions aimed at the prevention of weight gain in adults. Public Health Nutr. 2009;12(11):2236-46. [pmid: 19650959].
10 Hutfless S, Maruther NM, Wilson RF, Gudzune KA, Brown R, Lau B, Fawole OA, Anderson CAM, Segal JB. Strategies To Prevent Weight Gain Among Adults. Comparative Effectiveness Review No. 97. (Prepared by the Johns Hopkins University Evidence-based Practice Center under Contract No. 290-2007-10061-I.) AHRQ Publication No. 13-EHC029-EF. Rockville, MD. Agency for Healthcare Research and Quality. March. 2013. www.effectivehealthcare.ahrq.gov.
11 Robinson KA, Saldanha IJ, Mckoy NA. Frameworks for determining research gaps during systematic reviews. Methods Future Research Needs Report No. 2. (Prepared by the Johns Hopkins University Evidence-based Practice Center under Contract No. 290-2007-10061-I.) AHRQ Publication No. 11-EHC043-EF. Rockville, MD. Agency for Healthcare Research and Quality. June. 2011. www.ncbi.nlm.nih.gov/books/NBK62478/. Accessed June 22, 2012.
12 Bennett WL, Nicholson WK, Saldanha IJ, Wilson LM, Mckoy NA, Robinson KA. Future Research Needs for the Management of Gestational Diabetes. Future Research Needs Paper No. 7. (Prepared by Johns Hopkins University under Contract No. 290-2007-10061-I.) AHRQ Publication No. 11-EHC005-EF. Rockville, MD. Agency for Healthcare Research and Quality. November. 2010. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
13 Jones J, Hunter D. Consensus methods for medical and health services research. BMJ. 1995;311(7001):376-80. [pmid: 7640549].
14 Gregg EW, Cheny YJ, Cadwell BL, et al. Secular trends in cardiovascular disease risk factors according to body mass index in US adults. JAMA. 2005;293(15):1868-74. [pmid: 15840861].
15 Winkleby MA, Kraemer HC, Ahn DK, et al. Ethnic and socioeconomic differences in cardiovascular disease risk factors: findings for women from the Third National Health and Nutrition Examination Survey, 1988-1994. JAMA. 1998;280(4):356-62. [pmid: 9686553].
16 Freemantle N, Harvey EL, Wolf F, et al. Printed educational materials: effects on professional practice and health care outcomes. Cochrane Database Syst Rev. 2000;(2):CD000172. [pmid: 10796502].
17 Bandura A. Social Foundations of Thought and Action: A Social Cognitive Theory. Englewood Cliffs, NJ. Prentice-Hall. 1986.
18 Williamson DF. Descriptive epidemiology of body weight and weight change in U.S. adults. Ann Intern Med. 1993;119(7 Pt 2):646-9. [pmid: 8363190].
19 Guh DP, Zhang W, Bansback N, et al. The incidence of co-morbidities related to obesity and overweight: a systematic review and meta-analysis. BMC Public Health. 2009;9:88. [pmid: 19320986].
20 Trogdon JG, Finkelstein EA, Hylands T, et al. Indirect costs of obesity: a review of the current literature. Obes Rev. 2008;9(5):489-500. [pmid: 18331420].