# Executive Summary

## Background

The most recent estimates classify more than 35 percent of U.S. adults as obese. Obesity has been linked to increased risk of diseases such as hypertension, diabetes mellitus, kidney disease, and cancer; decreased life expectancy; and increased costs. Healthy People 2020 identified preventing weight gain and the development of obesity as a priority area, specifically to increase the prevalence of a healthy weight among adults from 31 percent to 34 percent and reduce the prevalence of obesity among adults to less than 30 percent. Despite this goal, we know of no treatment guidelines for the prevention of weight gain or maintenance of weight.

In 2012, the Johns Hopkins University Evidence-based Practice Center completed a comparative effectiveness review (CER) funded by the Agency for Healthcare Research and Quality on the comparative effectiveness of strategies to prevent weight gain in adults. Prior systematic reviews on weight gain prevention were limited by the inclusion of studies that included a weight loss component or measured only short-term outcomes (less than 12 months). Understanding what strategies are the most effective to prevent weight gain in adults may help establish treatment guidelines in order to achieve the Healthy People 2020 goal to increase the prevalence of a healthy weight among adults to 34 percent. The report, “Strategies To Prevent Weight Gain Among Adults,” released in 2013 (www.effectivehealthcare.ahrq.gov/reports/final.cfm), focused on the six Key Questions listed in Table A.

Table A Key Questions of the comparative effectiveness review

Number | Question
KQ1. | What is the comparative effectiveness of self-management strategies for the prevention of weight gain among adults?
KQ2. | What is the comparative effectiveness of dietary strategies for the prevention of weight gain among adults?
KQ3. | What is the comparative effectiveness of physical activity strategies for the prevention of weight gain among adults?
KQ4. | What is the comparative effectiveness of medications for the prevention of weight gain among adults?
KQ5. | What is the comparative effectiveness of a combination of self-management, dietary, physical activity, and medication strategies for the prevention of weight gain among adults?
KQ6. | What is the comparative effectiveness of environment level strategies for the prevention of weight gain among adults?

Abbreviation: KQ = Key Question

In the CER, the authors graded almost all of the evidence as low or insufficient in strength to address the Key Questions. As a result, all research questions were identified as gaps in the literature, limiting the report authors' ability to answer the Key Questions and make conclusions. The authors also identified broader methodological issues that limited the quality of available studies and resulted in the downgrading of the evidence.

## Methods

We identified potential research needs by abstracting research gaps from the CER and gaps identified by the authors of the report during in-person discussions. We also searched the National Institutes of Health's clinicaltrials.gov Web site to identify any ongoing clinical trials that may address the Key Questions proposed in the CER. Since all research questions were identified as gaps in the literature, we used a Delphi process with our stakeholders to prioritize evidence gaps using PICOTS elements (population, intervention, comparison, outcome, timing, setting) that need future research.

We recruited a diversity of stakeholders to represent various groups with potential interest in weight gain prevention, such as patients, physicians, researchers, insurers, employers, and funding agencies. Stakeholders were recruited via email and completed all rounds of the Delphi process using Web-based surveys. Stakeholders were directed to read the Executive Summary of the 2012 draft of the CER and use this document to inform their answers.

We created a list of crucial questions for future research using the PICOTS elements identified as high-priority research gaps, which our stakeholders prioritized again through a Delphi process. Based on the identified high-priority research needs, we created a matrix of potential research questions. Stakeholders were directed to evaluate research questions based on their potential to positively impact health and public health.

## Results

Using the PICOTS framework, stakeholders prioritized all adults, young adults, healthy-weight adults, and overweight adults according to their prevalence in the U.S. population and the potential health benefits of preventing the development of obesity in these groups (Figure A).

Figure A Framework for future research on strategies for the prevention of adult weight gain to address high-priority evidence gaps

Note: BMI = body mass index

Figure A illustrates the analytic framework for identification of potential research gaps. The framework identifies possible gaps in the research that has been done in strategies to prevent weight gain in adults. The figure includes a list of gaps regarding strategies to prevent weight gain in adults.

Stakeholders identified combination interventions as the priority for future research. They stated that multiple factors contribute to weight gain. Therefore, they felt that interventions would need to address multiple factors, which would likely require multiple components. Stakeholders selected interventions that combined either self-management, diet, and exercise or self-management, diet, exercise, and environmental alterations as the two highest priority combinations of interventions. However, in selecting comparisons of interventions that would be of greatest priority, stakeholders downgraded interventions that included environmental approaches (not included in Figure A). The two highest priority comparisons of interest were self-management and diet versus either self-management and exercise or self-management, diet, and exercise. Stakeholders prioritized three settings for the interventions to take place: work, home, and community. These settings were selected because adults spend the majority of their time in these three locations, and that is where they interact with other people who are likely to have some influence on their habits and behaviors.

Stakeholders identified the primary outcome of interest for all interventions as weight gain prevention. Because no standard definition of weight maintenance exists, all stakeholders agreed that the field of weight gain prevention would benefit from the establishment of a standard definition. This definition would ensure that future studies of weight gain prevention have an adequate duration of followup to confirm weight maintenance and also improve comparability of results across studies. In addition, stakeholders identified two priority secondary outcomes that should be assessed in future interventions (Figure A). First, they felt that adherence was a critical intermediate outcome in evaluating the efficacy of the intervention and identifying subgroups that may be most responsive to a particular intervention. Second, the stakeholders identified weight-related clinical conditions, including cardiovascular disease and diabetes, as important secondary outcomes. Their justification was that interventions that not only prevent weight gain but also prevent or reduce the incidence of weight-related diseases would have a significant public health impact.

In their response to the matrix of questions, stakeholders identified seven research questions and one methodologic question as high priorities for future research (Table B). Stakeholders stated that creating a standard definition of weight maintenance was critical to helping researchers confirm true weight maintenance over time, as well as to increase comparability of results across studies.

Table B Questions prioritized for future research

Research Questions
To prevent weight gain in all adults, what is the comparative effectiveness of adding physical activity versus not adding physical activity to a work-based self-management and diet intervention?
To prevent weight gain in all adults, what is the comparative effectiveness of adding physical activity versus not adding physical activity to a home-based self-management and diet intervention?
To prevent weight gain in all adults, what is the effectiveness of a work-based self-management and physical activity intervention versus a self-management and diet intervention?
To prevent weight gain in all adults, what is the effectiveness of a home-based self-management and physical activity intervention compared with a self-management and diet intervention?
To prevent weight gain in overweight adults, what is the comparative effectiveness of adding physical activity versus not adding physical activity to a home-based self-management and diet intervention?
To prevent weight gain in overweight adults, what is the effectiveness of a home-based self-management and physical activity intervention compared with a self-management and diet intervention?
To prevent weight gain in young adults, what is the comparative effectiveness of adding physical activity versus not adding physical activity to a home-based self-management and diet intervention?
Methodologic Question
What is a clinically meaningful definition of weight maintenance among adults, expressed as both weight (kg) and body mass index (kg/m^2^),that can be used as the standard across studies of weight gain prevention?

## Discussion

Using the draft of the 2013 CER “Strategies To Prevent Weight Gain Among Adults,” we identified and prioritized future research needs. We identified seven research questions that a multidisciplinary group of stakeholders considered to have great potential health impact. We also identified one methodologic question considered to be of critical importance to the advancement of the weight gain prevention field. This report will help researchers to develop studies evaluating the questions identified, as well as enable funding agencies to dedicate their resources to areas most likely to make a health impact.

The populations denoted in our research questions are likely to achieve significant health benefits with the avoidance of obesity. We would also encourage researchers to consider recruiting subgroups at high risk of obesity such as adults with cardiovascular disease or diabetes and low-income adults. We recommend that researchers consider designing head-to-head comparison interventions that combine self-management and diet intervention with a self-management and exercise intervention or compare a self-management and diet intervention with a self-management, diet, and exercise intervention. These combination interventions might use a multidimensional approach that consists of a specific diet or exercise plan, counseling, and the use of tailored self-management strategies. Given the findings from this report, these comparisons of interventions should occur either in the work or home setting. In addition to measuring the interventions' effect on weight or body mass index, future studies should measure and evaluate adherence, as well as the impact of the intervention on the prevention or reduction of weight-related clinical outcomes.

This project was limited by the large number of evidence gaps, which made it unfeasible to present all research questions developed from these gaps to our stakeholders. Therefore, we used a method that relied heavily on input from the CER authors and the stakeholders to identify priority gaps and key research questions. We feel that the questions developed, if answered, can impact much of the population and are appropriate first steps in increasing the breadth and quality of the evidence base in the field of adult weight gain prevention.

## Conclusions

Using the draft CER “Strategies To Prevent Weight Gain Among Adults,” we identified and prioritized future research needs. We identified seven research questions that a multidisciplinary group of stakeholders considered to be of potential health impact. These questions focus on high-priority populations, interventions, comparisons, and settings identified by our stakeholders. We also identified a methodologic research question regarding the creation of a standard definition of weight maintenance that all of our stakeholders agreed would benefit the overall field of weight gain prevention. This report may inform and support researchers to develop studies to evaluate the research questions identified, as well as enable funding agencies to dedicate their resources to areas most likely to make a health impact.