# Addendum

August 5, 2013

The report Strategies To Prevent Weight Gain in Adults: Future Research Needs was posed for public comment from June 27, 2013, to July 26, 2013, on the Effective Health Care Program Web site. We received three sets of comments.

In response to the comments received, the authors add the following discussion point:

- Adults with physical disability may need to be considered as an additional subgroup at high risk for obesity and targeted for weight gain prevention interventions. If this group is selected, then investigators should consider including additional outcome measures such as health-related quality of life and physical function.

All other comments were related to gaps outside the scope of the original systematic review including endocrine and hormonal causes of weight gain, and the association of geographic positioning data and weight gain. These comments were considered, and no other changes were made in this report.