# Acknowledgments

The Johns Hopkins University Evidence-based Practice Center thanks the other authors of the comparative effectiveness review on weight gain prevention in adults and the stakeholders (each listed below).

## Contributors

- Caroline Apovian, M.D., FACP, FACN
  Boston Medical Center
  Boston, MA
- Bethany Barone Gibbs, Ph.D.
  University of Pittsburgh
  Pittsburgh, PA
- Kathy McCaskey
  Patient Stakeholder
  Lancaster, PA
- Jeri Miller, Ph.D.
  National Institutes of Health
  Bethesda, MD
- Richard Safeer, M.D.
  Johns Hopkins HealthCare
  Baltimore, MD
- Selen Saydam
  Patient Stakeholder
  Columbia, MD
- Lindsey Wilsnack
  Employer Representative
  Baltimore, MD