# Discussion

Using the 2012 version of the CER “Strategies To Prevent Weight Gain Among Adults,”10 we identified and prioritized future research needs. We identified seven research questions considered to be of potential health impact by a multidisciplinary group of stakeholders. We believe that this report will help researchers to develop studies evaluating the Key Questions identified, as well as enable funding agencies to dedicate their resources to areas most likely to make a health impact.

The populations within our research questions purposely target broad audiences (all adults, young adults, and overweight adults) who are likely to achieve significant health benefit from preventing the development of obesity. Our stakeholders preferred a broad population, given the lack of evidence in this field. However, our stakeholders did consider adults with cardiovascular disease or diabetes and low-income adults to be high-priority subgroups, given their high risk of obesity.14,15 We would encourage researchers to specifically recruit representatives from these subgroups in future research studies with an a priori plan for subgroup analyses.

Our stakeholders selected head-to-head comparisons of specific combinations of interventions as priority comparisons in our research questions. We feel that the lack of these head-to-head comparisons is a significant evidence gap, as most studies identified in the CER compared intervention to usual care/control. These head-to-head comparisons would likely provide critical insight into the creation of guidelines to prevent weight gain, as these types of comparisons represent real clinical conundrums that patients and health care providers face daily. The first pairing compares a self-management and diet intervention to a self-management and exercise intervention to answer the question of whether diet or exercise is superior to prevent weight gain. The second pairing compares a self-management and diet intervention to a self-management, diet, and exercise intervention to answer whether the addition of exercise to diet is superior to diet alone in preventing weight gain. We recommend that future diet and/or exercise interventions have a multidimensional approach in order to successfully result in behavior change. These approaches should combine a specific diet or exercise plan with either individual or group counseling and the use of tailored self-management strategies. Printed educational materials were not selected as a priority intervention strategy, and prior evidence has shown that such methods are unlikely to result in behavior change.16

Our research questions also target only work or home settings, as adults spend the majority of their time there. Family, friends, and colleagues in these places are also likely to influence behavior through mechanisms such as social influence, norms, and modeling.17 We would discourage future studies from relying on clinic-based interventions, as health care providers typically have limited time and training to perform the multicomponent interventions described above.

With respect to outcomes, we identified weight or body mass index as the prevailing measures of choice. However, no standard definition of weight maintenance exists. In the CER, the authors defined weight maintenance as 0.5 kg over 12 months, which was based upon the predicted average weight gain of an adult.18 We recommend that future research in this field should first address this major methodologic gap by creating a standard definition of weight maintenance. Our stakeholders felt that this definition should include standards for change in both weight and body mass index over a prespecified time period, given the common use of both these measures. In addition, we feel that the definition should be clinically relevant and be associated with the prevention or reduction of weight-related comorbidities such as hypertension and diabetes mellitus as well as mortality. The establishment of this definition would help future researchers ensure that their trials are designed to actually evaluate weight gain prevention and would facilitate the comparability of weight gain prevention across studies.

In addition to the primary outcome of weight gain prevention, certain secondary outcomes need to be evaluated in future studies that address our priority research questions. First, all interventional studies should assess adherence to the intervention. Adherence is essential in understanding whether and in whom certain interventions work best. This knowledge is critical in translating an approach to a different population or scaling up a successful program. Second, studies should also evaluate the effect of the intervention or approach on weight-related clinical outcomes. In the CER, the authors included cardiovascular disease, diabetes mellitus, infertility, degenerative joint disease, and liver disease as outcomes of interest. Our stakeholders also agreed that these weight-related clinical outcomes would be of interest in future studies. Interventions that prevent weight gain, as well as prevent or reduce these conditions linked with high morbidity and costs to both the health care system and society, will have significant public health impact.

There are some limitations of this project. The large number of evidence gaps made it unfeasible to create and present all research questions from these gaps to our stakeholders, which would be a more standard approach to identifying future research needs. We modified the approach piloted in a prior future research needs report12 for this purpose. This method relied heavily on input from the authors of the CER and the stakeholders, who all have their own priorities and biases that influence their perceptions of the topic and reflections on the CER process. We feel that the questions developed would influence a broad audience and are appropriate first steps in increasing the breadth and quality of the evidence base in the field of adult weight gain prevention.

There are several strengths to this report. Our research team included several members of the original report's research team, which provided ready access to their insight on the process of the CER and challenges experienced by that original team. We also recruited stakeholders to represent a variety of interests. The prevention of adult weight gain is not only important to patients, health care providers, and researchers, but is also of particular interest to health insurers and employers, given that obesity has been associated with increased morbidity,2,19 health care costs,4 and decreased workplace productivity.20 We also had high levels of participation from our stakeholders at each step. We feel that our diverse array of engaged stakeholders helps to ensure that the priority questions we developed will be of significant public health impact. Finally, we encouraged stakeholders to provide comments in addition to performing rankings. This qualitative component gave important insight on the thought process behind many of the stakeholders' choices and added an additional element of richness to the data we collected.