# Conclusion

Using the CER “Strategies To Prevent Weight Gain Among Adults,” we identified and prioritized future research needs. We identified seven research questions considered to be of potential health impact by a multidisciplinary group of stakeholders. These questions focus on high-priority populations, interventions, comparisons, and settings identified by our stakeholders. We also identified a methodologic research question regarding the creation of a standard definition of weight maintenance that all of our stakeholders agreed would benefit the overall field of weight gain prevention. This report may inform and support researchers to develop studies to evaluate the priority questions identified, as well as enable funding agencies to dedicate their resources to areas most likely to make a health impact.