# Background

## Context

The most recent estimates classify more than 35 percent of U.S. adults as obese.1 Obesity has been linked to increased risk of diseases such as hypertension, diabetes mellitus, kidney disease, and cancer;2 decreased life expectancy;3 and increased costs.4 Healthy People 2020 identified preventing weight gain and the development of obesity as a priority area, specifically to increase the prevalence of a healthy weight among adults from 31 percent to 34 percent and reduce the prevalence of obesity among adults to less than 30 percent.5 Despite this goal, we know of no treatment guidelines for the prevention of weight gain or maintenance of weight.

Prior systematic reviews have focused on weight loss or weight maintenance after weight loss,6,7 and the few systematic reviews on weight gain prevention included studies that targeted weight loss or reported outcomes at less than 12 months, which we would not consider true weight maintenance.8,9 Therefore, a synthesis of the literature on long-term weight gain prevention was needed. The Johns Hopkins University Evidence-based Practice Center carried out a comparative effectiveness review (CER), funded by the Agency for Healthcare Research and Quality (AHRQ), on the comparative effectiveness of strategies to prevent weight gain among adults.10 The draft review, completed in 2012, was used for the study of future research needs; the CER was posted in 2013. The report focused on six Key Questions, listed in Table 1.

Table 1 Key Questions of the comparative effectiveness review

Number | Question
KQ1 | What is the comparative effectiveness of self-management strategies for the prevention of weight gain among adults?
KQ2 | What is the comparative effectiveness of dietary strategies for the prevention of weight gain among adults?
KQ3 | What is the comparative effectiveness of physical activity strategies for the prevention of weight gain among adults?
KQ4 | What is the comparative effectiveness of medications for the prevention of weight gain among adults?
KQ5 | What is the comparative effectiveness of a combination of self-management, dietary, physical activity, and medication strategies for the prevention of weight gain among adults?
KQ6 | What is the comparative effectiveness of environment level strategies for the prevention of weight gain among adults?

Abbreviation: KQ = Key Question

The report authors identified 58 publications describing 51 studies. No tested interventions or described approaches in observational studies achieved a high strength of evidence to prevent weight gain in adults. From this body of literature, the authors made the following conclusions: (1) work-based interventions that combine self management, diet, physical activity, and/or environmental strategies prevent weight gain as compared to control, and (2) home-based aerobic and resistance exercise prevent weight gain among women with cancer, as these interventions were rated as having moderate strength of evidence. These studies compared their interventions with control or usual care. The report authors graded almost all evidence as low or insufficient in strength to address the Key Questions.

Overall, the report had limited ability to answer the Key Questions or draw conclusions, given the lack of high-quality evidence in this field. Much of the existing evidence was downgraded to low strength of evidence due to study designs and methods that were considered to be either at high risk for bias for reasons such as lack of blinding of outcome assessors or imprecise due to a lack of reporting of variance measures. Additionally, weight gain prevention was not the stated goal for many studies included in the review. Other comparisons were graded as insufficient, as no studies were identified that addressed those specific questions, such as examining any intervention among adults with low socioeconomic status.

## Evidence Gaps

The CER suggests that future research separately examine interventions to prevent weight gain among healthy-weight, overweight, and obese individuals. The report also places a priority on designing interventions for adults with severe mental illness taking antipsychotics and for diabetics taking certain oral medications or insulin, given their high risk of weight gain, attributed in part to side effects from these medications.

The CER also notes several methodological and reporting limitations that should be considered during the design of future studies. The authors state that studies designed to measure weight over time are more likely to collect high-quality weight measurements and have adequate power to study weight gain prevention; therefore, observational cohorts should make measuring weight a stated goal in their protocols. In addition, intervention trials should be of sufficient duration (longer than 12 months) to assess the efficacy of weight gain prevention intervention. The authors conclude that longer followup will help to identify true effectiveness (weight gain of only 0.5 kg per year, which was the definition of weight maintenance used in the report).

## Objective

In this report, we aimed to establish key areas for future adult weight gain prevention research by developing a prioritized list of research needs with considerations for potential research designs for researchers and funders to use for developing research proposals or solicitations.