# Ongoing/Recently Completed Studies Related to Adult Weight Maintenance Search Strategies

Appendix Table 1 Search strategies for ongoing studies

Resource URL | Search Parameters | Search Terms/Strategy
ClinicalTrials.gov http://clinicaltrials.gov/ | Advanced search, Conditions field used | Prevent adult weight gain OR adult weight maintenance
EU Clinical Trials Register https://www.clinicaltrialsregister.eu/ | Not applicable | Prevent adult weight gain OR adult weight maintenance
NIH Reporter http://projectreporter.nih.gov/reporter.cfm | Projects field searched | Prevent adult weight gain OR adult weight maintenance
Canadian Institute for Health Research http://www.cihr-irsc.gc.ca/ | Funding Decisions Data field searched | Prevent adult weight gain OR adult weight maintenance
World Health Organization International Clinical Trials Registry Platform Search Portal http://apps.who.int/trialsearch/ | Searched Condition field, Recruitment status = ALL | Prevent adult weight gain OR adult weight maintenance

Appendix Table 2 Index of ongoing/recently completed studies potentially applicable to Key Questions from Comparative Effectiveness Review “Strategies To Prevent Weight Gain Among Adults”

Study Title | URL | Status
Move and Moderate in Balance | http://ClinicalTrials.gov/show/NCT00715130 | Recently Completed
Diet and Physical Activity Interactions in Obesity | http://ClinicalTrials.gov/show/NCT00067964 | Recently Completed
Prevention of Weight Gain | http://ClinicalTrials.gov/show/NCT00011102 | Recently Completed
Walking For Wellness Program Evaluation | http://ClinicalTrials.gov/show/NCT00156351 | Recently Completed
Long-Term Exercise Maintenance Via Internet Support | http://ClinicalTrials.gov/show/NCT00260117 | Recently Completed
Strength Training for Obesity Prevention | http://ClinicalTrials.gov/show/NCT00030160 | Recently Completed
Effect of Exercise on Prevention of Weight Gain | http://ClinicalTrials.gov/show/NCT00177502 | Recently Completed
Veterans Enhanced Fitness Study | http://ClinicalTrials.gov/show/NCT00594399 | Recently Completed
Study of Impact of Behavioral Intervention- Exercise; Nutrition; Education- on Body Mass Index (BMI) | http://ClinicalTrials.gov/show/NCT00132132 | Recently Completed
A Physical Activity and Diet Program to Prevent Accumulation of Abdominal Fat Mass in Recently Retired Men and Women | http://ClinicalTrials.gov/show/NCT00122213 | Recently Completed
LIFT: Lifestyle Interventions For Two | http://ClinicalTrials.gov/show/NCT01616147 | Ongoing
Promoting Activity and Changes in Eating (PACE) to Reduce Obesity | http://ClinicalTrials.gov/show/NCT00119782 | Ongoing
Make Better Choices | http://ClinicalTrials.gov/show/NCT01249989 | Ongoing
Maintenance After Initiation of Nutrition Training | http://ClinicalTrials.gov/show/NCT01357551 | Ongoing
An Intergenerational Community Based Participatory Research (CBPR) Intervention to Reduce Appalachian Health Disparities | http://ClinicalTrials.gov/show/NCT01373307 | Ongoing
Study of Ongoing Approaches for Prevention | http://ClinicalTrials.gov/show/NCT01183689 | Ongoing
Helping People to Exercise Regularly | http://ClinicalTrials.gov/show/NCT01335880 | Ongoing
Whole Grain Polyphenol Bioavailability and Effects on Health | http://ClinicalTrials.gov/show/NCT01293175 | Ongoing
Planned CORR: Planned Care for Obesity and Risk Reduction | http://ClinicalTrials.gov/show/NCT01134029 | Ongoing
African American Church-based Cohort | http://ClinicalTrials.gov/show/NCT00823394 | Ongoing
Tu Salud Si Cuenta Media Campaign | http://ClinicalTrials.gov/show/NCT00788879 | Ongoing
Efficacy of Lifestyle Changes in Modifying Practical Markers of Wellness and Aging | http://ClinicalTrials.gov/show/NCT00395837 | Ongoing
Calorie Restriction and Changes in Body Composition; Disease; Function; and Quality of Life in Older Adults | http://ClinicalTrials.gov/show/NCT00955903 | Ongoing
A Randomized Clinical Trial of Home-based Exercise Combined With a Slight Caloric Restriction on Obesity Prevention Among Women | http://ClinicalTrials.gov/show/NCT01206413 | Recently Completed
The Women's Healthy Lifestyle Study | http://ClinicalTrials.gov/show/NCT00583726 | Recently Completed
Lifestyle Intervention for Pakistani Women in Oslo | http://ClinicalTrials.gov/show/NCT00425269 | Recently Completed
Healthy Mothers on the Move | http://ClinicalTrials.gov/show/NCT01584063 | Recently Completed
Childhood Obesity Prevention | http://ClinicalTrials.gov/show/NCT00630617 | Recently Completed
Nutrition Intervention and Play Group Exercise for Low-Income Latinas | http://ClinicalTrials.gov/show/NCT00454948 | Ongoing
Community Based Obesity Prevention Among Black Women | http://ClinicalTrials.gov/show/NCT00938535 | Ongoing
Fit Over 45 - a Health Promotion Project for Inactive Female Hospital Staff Age 45+ From the University Hospital of Zürich | http://ClinicalTrials.gov/show/NCT01033110 | Ongoing
The Mediterranean Diet and Lactation Study: A Diet Study in Lactating Women | http://ClinicalTrials.gov/show/NCT01459991 | Ongoing
eMOMS of Rochester: Electronically-Mediated Weight Interventions for Pregnant and Postpartum Women | http://ClinicalTrials.gov/show/NCT01331564 | Ongoing
Healthy Homes/Healthy Families | http://ClinicalTrials.gov/show/NCT01326897 | Ongoing
Family Program for Weight Gain Prevention | http://ClinicalTrials.gov/show/NCT00989170 | Ongoing
Study of a Smart Growth Community's Effect on Prevention of Obesity in Middle-; Moderately Low- and Low-Income Families | http://ClinicalTrials.gov/show/NCT00986011 | Ongoing
Health Promotion of People With Disabilities | http://ClinicalTrials.gov/show/NCT00164489 | Recently Completed
Weight Management and Coping Skills Training For Patients With Knee Osteoarthritis | http://ClinicalTrials.gov/show/NCT00305890 | Recently Completed
Longitudinal Study of Weight Change Following Lower Limb Amputation | http://ClinicalTrials.gov/show/NCT00932399 | Ongoing
A Study on Induced Weight Gain During Atypical Antipsychotic Treatment and Its Management With Psychoeducational Programme | http://ClinicalTrials.gov/show/NCT00191828 | Recently Completed
The Effect of a Weight Management Program During Treatment With Olanzapine | http://ClinicalTrials.gov/show/NCT00169702 | Recently Completed
Effect of Dietary and Life Style Modification on Post Liver Transplant Obesity | http://ClinicalTrials.gov/show/NCT00878592 | Ongoing
CCRC: Understanding the Effects of Omega-3 Fatty Acids Versus Lignans in Flaxseed on Metabolic and Inflammatory Markers Leading to Diabetes and Cardiovascular Disease | http://ClinicalTrials.gov/show/NCT00935922 | Recently Completed
Reduced Cardiac Rehabilitation Program | http://ClinicalTrials.gov/show/NCT01483235 | Recently Completed
Shared Decision-Making: Effects on Cardiac Risk Factor Modification Behavior | http://ClinicalTrials.gov/show/NCT00714935 | Recently Completed
PBWST (Partial Body-Weight Supported Treadmill Training) and Muscle Power Training After Sub-Acute Stroke | http://ClinicalTrials.gov/show/NCT00108030 | Recently Completed
The Effects of Health Education in Cardiovascular Diseases Prevention and Treatment | http://ClinicalTrials.gov/show/NCT01426282 | Recently Completed
Cardiovascular Risk Reduction Program Aimed at African American Women (The HHER Lifestyle Program) | http://ClinicalTrials.gov/show/NCT00860444 | Recently Completed
A Randomized Controlled Trial of a Community-based Primary and Secondary Cardiovascular Prevention Program | http://ClinicalTrials.gov/show/NCT00236210 | Recently Completed
Walking Away: Structured Education Versus Written Information for Individuals With High Risk of Developing Type 2 Diabetes | http://ClinicalTrials.gov/show/NCT00941954 | Ongoing
Japan Diabetes Optimal Integrated Treatment Study for 3 Major Risk Factors of Cardiovascular Diseases | http://ClinicalTrials.gov/show/NCT00300976 | Ongoing
Use of Information Technology in the Prevention of Diabetes | http://ClinicalTrials.gov/show/NCT00819455 | Ongoing
A Culturally Tailored Lifestyle Intervention to Prevent Diabetes in South Asians | http://ClinicalTrials.gov/show/NCT01084928 | Ongoing
Impact of Lifestyle Intervention Programs on Glucose Metabolism and Biomarkers for Type 2 Diabetes: Ethnical Aspects | http://ClinicalTrials.gov/show/NCT01420198 | Ongoing
Peer-led and Telehealth Comparative Effectiveness Research (CER) Adoption for Diabetes Prevention and Management | http://ClinicalTrials.gov/show/NCT01307137 | Ongoing
Jordan Diabetes Microclinic Project | http://ClinicalTrials.gov/show/NCT01596244 | Ongoing
The Diabetes TeleCare Study | http://ClinicalTrials.gov/show/NCT00288132 | Ongoing
A Randomized Trial of an Intensive Education Intervention Using a Network of Involved Diabetic Patients (Peer Educators) to Improve Glycemic Control of Type 2 Diabetic Patients | http://ClinicalTrials.gov/show/NCT01485913 | Ongoing
Can a Modified Fat Diet With Low Glycaemic Load Improve Insulin Sensitivity and Inflammatory Mediators in Overweight People With Chronic Heart Failure? | http://ClinicalTrials.gov/show/NCT00163904 | Ongoing
Risk Reduction in Coronary Heart Disease - a Prospective Randomized Study | http://ClinicalTrials.gov/show/NCT00679237 | Ongoing
Step Monitoring to Improve ARTERial Health | http://ClinicalTrials.gov/show/NCT01475201 | Ongoing
Effect of Balanced Hypocaloric Diet Associated with Supplementation of Eggplant Meal in the Remission of Cardiovascular Risk Factors | http://ClinicalTrials.gov/show/NCT01622309 | Ongoing
Study of Macronutrients and Heart Disease Risk | http://ClinicalTrials.gov/show/NCT00609271 | Ongoing
Workplace-Sponsored Program to Reduce Obesity | http://ClinicalTrials.gov/show/NCT00123513 | Recently Completed
Worksite Program to Prevent Weight Gain Among Bus Drivers | http://ClinicalTrials.gov/show/NCT00122993 | Recently Completed
A Cafeteria Based Study of Weight Gain Prevention | http://ClinicalTrials.gov/show/NCT00573482 | Recently Completed
Preventing Obesity in the Worksite: A Multi-Message; Multi-\Step\' Approach' | http://ClinicalTrials.gov/show/NCT01585480 | Recently Completed
Work; Weight; and Wellness Program: The 3W Program | http://ClinicalTrials.gov/show/NCT00123019 | Recently Completed
Workplace Intervention: Activity Monitoring as a Tool for Corporate Wellness and Weight Loss | http://ClinicalTrials.gov/show/NCT01461382 | Recently Completed
Peer Education; Exercising and Eating Right - Obesity Prevention in Freshmen Women | http://ClinicalTrials.gov/show/NCT01043614 | Recently Completed
School Intervention With Daily Physical Activity and Healthy Food for Students With an Intellectual Disability | http://ClinicalTrials.gov/show/NCT01291238 | Recently Completed
Diabetes Prevention and Control in the Workplace: A Pilot Study | http://ClinicalTrials.gov/show/NCT00739336 | Ongoing
Efficacy of \Tailored Physical Activity\‘ in Health Care Workers’ | http://ClinicalTrials.gov/show/NCT01543984 | Ongoing
A Web-Based Cardiovascular Intervention for the Workplace | http://ClinicalTrials.gov/show/NCT00763308 | Ongoing
Wellness Program for Elementary School Personnel | http://ClinicalTrials.gov/show/NCT00123500 | Ongoing
School Worksite Weight Gain Prevention Intervention Study | http://ClinicalTrials.gov/show/NCT01467284 | Ongoing
Choosing Healthy Options in College Environments and Settings | http://ClinicalTrials.gov/show/NCT01134783 | Ongoing
Prevention of Obesity at Universities: A Randomized Trial | http://ClinicalTrials.gov/show/NCT00456131 | Ongoing
DAMES: Daughters And MothErS Against Breast Cancer | http://ClinicalTrials.gov/show/NCT00630591 | Recently Completed
Weight Gain Prevention for Breast Cancer Survivors | http://ClinicalTrials.gov/show/NCT00533338 | Ongoing
Exercise Program of Breast Cancer Patients Undergoing Chemotherapy With or Without Radiation | http://ClinicalTrials.gov/show/NCT01157767 | Ongoing
Effects of Physical Activity and Dietary Change in Minority Breast Cancer Survivors | http://ClinicalTrials.gov/show/NCT00811824 | Ongoing
Weight Control Programs in Women Who Have Undergone Surgery for Early Stage Breast Cancer | http://ClinicalTrials.gov/show/NCT00869466 | Ongoing
Individual Counseling and/or Computer-Based Counseling in Helping Healthy Women Adopt a Cancer Prevention Diet | http://ClinicalTrials.gov/show/NCT00217490 | Ongoing
Energy Balance Interventions for Colorectal Cancer Prevention | http://ClinicalTrials.gov/show/NCT00653484 | Ongoing
Isoflavones in Preventing Further Development of Cancer in Patients With Stage I or Stage II Prostate Cancer | http://ClinicalTrials.gov/show/NCT00027950 | Ongoing