# Results

Based on the 2012 CER and our discussion with stakeholders, we identified the 15 potential research areas listed in Table 4. Not all areas were considered within the scope of the 2012 CER; these out-of-scope areas are highlighted in italics. Since these areas were out of scope for the original review, it is unclear whether large evidence gaps exist for these areas; however, they were identified and deemed potentially important by the stakeholder panel. During the second stakeholder call, it was decided to remove the research area listed as number 13 in Table 4 (What are the risks, benefits, and costs of different treatments for CAD, stratified by gender?). Both the stakeholders and the EPC team felt that this research area encompassed all other research areas in the list, and for this reason received a score almost twice as high as the next-highest ranked area. Thus, this research area was skewing the rankings because participants were using most of their ranking points on it and had few left for the remaining research areas. In the final stakeholder ranking, 9 of the 10 stakeholders participated and ranked the 14 final research priorities. The final ranking is listed below in Table 5 and is divided into a top, middle, and lower tier, based on the overall score.

Table 5 Final ranking of Future Research Needs for treatment strategies for women with CAD

Tier | Question | Score
Top Tier | What is the effectiveness of the following treatment strategies on short-, intermediate- or long-term clinical outcomes (nonfatal MI, death, stroke, repeat revascularization, recurrent unstable angina, heart failure, repeat hospitalization, length of hospital stay, graft failure, angina relief, quality of life, or cognitive effects)? Revascularization (PCI or CABG) vs. optimal medical therapy in women with unstable angina | 13
Middle Tier | Is there evidence that the comparative effectiveness of PCI vs. fibrinolysis/supportive therapy in women with STEMI; early invasive vs. initial conservative therapy in women with UA/NSTEMI; or PCI vs. CABG or revascularization vs. optimal medical therapy in women with stable or unstable angina differs by such characteristics as: Coronary disease risk factors such as diabetes, chronic kidney disease, or other comorbid disease? | 5
Middle Tier | What is the effectiveness of the following treatment strategies on short-, intermediate- or long-term clinical outcomes (nonfatal MI, death, stroke, repeat revascularization, recurrent unstable angina, heart failure, repeat hospitalization, length of hospital stay, graft failure, angina relief, quality of life, or cognitive effects)? PCI vs. CABG in women with stable or unstable angina | 4
Middle Tier | What are the potential harms in women of PCI vs. CABG or revascularization vs. optimal medical therapy with stable or unstable angina? | 4
Middle Tier | Are the patient outcomes from real-world settings or observational registries similar to the findings from randomized clinical trials? * | 4
Middle Tier | Is there evidence that the comparative effectiveness of PCI vs. fibrinolysis/supportive therapy in women with STEMI; early invasive vs. initial conservative therapy in women with UA/NSTEMI; or PCI vs. CABG or revascularization vs. optimal medical therapy in women with stable or unstable angina differs by such characteristics as: Angiographic-specific factors (number of diseased vessels, vessel territory stenoses, left ventricular function, access site, or prior PCI or CABG revascularization procedure)? | 3
Middle Tier | Does patient preference or clinical specialty (primary care, cardiology, cardiothoracic surgery) affect the choice of treatment strategy (medical therapy or type of revascularization)? * | 3
Lower Tier | Is there evidence that the comparative effectiveness of PCI vs. fibrinolysis/supportive therapy in women with STEMI; early invasive vs. initial conservative therapy in women with UA/NSTEMI; or PCI vs. CABG or revascularization vs. optimal medical therapy in women with stable or unstable angina differs by such characteristics as: Age, race, or other demographic and socioeconomic risk factors? | 2
Lower Tier | In women presenting with STEMI: What is the effectiveness of PCI vs. fibrinolysis/supportive therapy on intermediate- or long-term clinical outcomes (nonfatal MI, death, stroke, repeat revascularization, recurrent unstable angina, heart failure, repeat hospitalization, length of hospital stay, angina relief, quality of life, or cognitive effects)? | 2
Lower Tier | In women presenting with UA/NSTEMI: What is the effectiveness of early invasive (PCI or CABG) vs. initial conservative therapy on short-, intermediate- or long-term clinical outcomes (nonfatal MI, death, stroke, repeat revascularization, recurrent unstable angina, heart failure, repeat hospitalization, length of hospital stay, graft failure, angina relief, quality of life, or cognitive effects)? | 2
Lower Tier | Are there gender differences in the instruments used to measure functional status, risk factors, comorbidities, etc. associated with CAD? * | 2
Lower Tier | What are the potential harms in women of early invasive vs. initial conservative therapy with UA/NSTEMI? | 2
Lower Tier | Is there evidence that the comparative effectiveness of PCI vs. fibrinolysis/supportive therapy in women with STEMI; early invasive vs. initial conservative therapy in women with UA/NSTEMI; or PCI vs. CABG or revascularization vs. optimal medical therapy in women with stable or unstable angina differs by such characteristics as: Hospital characteristics (hospital volume, setting, guideline-based treatment protocols)? | 1
Lower Tier | What are the potential harms in women of PCI vs. fibrinolysis/supportive therapy with STEMI? | 1

Abbreviations: CABG = coronary artery bypass graft surgery; CAD = coronary artery disease; MI = myocardial infarction; PCI = percutaneous coronary intervention; STEMI = ST elevation myocardial infarction; UA/NSTEMI = unstable angina/non-ST elevation myocardial infarction

* Out-of-scope research topics are highlighted in italics.

These final rankings were somewhat changed from the preliminary rankings provided by the stakeholders prior to the second call, as was expected after the removal of the highest-ranked research are from the preliminary exercise. Of note is that no studies were given a score of zero in the second ranking, while there were three studies with a score of zero in the first ranking, indicating that the removal of the overarching evidence gap allowed for a more complete ranking of these three gaps against each other. The second research area in the top tier, which was originally only separated from the next highest gap by two points, became the far and away highest ranked research gap. The remaining 13 gaps were not greatly separated from each other by score, which is similar to the results from the first ranking exercise. Two evidence gaps from the middle tier fell to the lower tier; these were related to angiographic factors affecting treatment type, and the potential harms in women of different treatments for stable and unstable angina. Only one lower tier evidence gap moved up to the middle tier, and its focus was on gender differences in the instrumentation used for CAD. Based on the stakeholder-identified top tier, the EPC team discussed potential study designs for each research area—these are listed in Table 6. While the proposed methods to address each area are not intended to be restrictive of potential study designs, this section is intended to discuss the benefits or limitations for each study design for answering these questions.

Table 6 High-priority research area and possible study designs

Research Area | RCT? | Meta-Analysis or Individual Patient Data Analysis Across RCTs? | Meta-Analysis of Observational Studies? | New Observational Study? | Analysis of Existing Data? | Model?
What is the effectiveness of the following treatment strategies on short-, intermediate- or long-term clinical outcomes (nonfatal MI, death, stroke, repeat revascularization, recurrent unstable angina, heart failure, repeat hospitalization, length of hospital stay, graft failure, angina relief, quality of life, or cognitive effects)? Revascularization (PCI or CABG) vs. optimal medical therapy in women with stable angina | Yes: RCT with women only or large enough sample size with stratification of randomization by sex to allow for meaningful sex-based analyses would provide most informative evidence | Maybe: Maybe appropriate if sufficient studies, including those studies that did not report sex-stratified outcomes | Yes: if the individual patient data is available from the observational studies and the short-, intermediate-, and long-term outcomes are ascertained the same way for the different treatment strategies | Maybe: if RCT is not feasible, then an observational study could explore the evidence gap though without the same fidelity | No: Unlikely to help as very few comparative studies currently exist with short-, intermediate, or long-term clinical outcomes for women with stable angina | Maybe: Potential role for helping determine clinically important differences

Abbreviations: CABG = coronary artery bypass graft surgery; MI = myocardial infarction; PCI = percutaneous coronary intervention; RCT = randomized controlled trial; STEMI = ST elevation myocardial infarction; UA/NSTEMI = unstable angina/non-ST elevation myocardial infarction