# Methods

## Overview

Our approach to identifying evidence gaps, prioritizing future research, and developing recommendations for stakeholders is outlined in the following steps. Further detail is provided below.

1. Develop an analytic framework from the original CER in order to understand the clinical and policy context of the review and its initial list of Future Research Needs.
2. Create an initial list of evidence gaps based on the CER organized according to the population, interventions, comparators, and outcomes (PICO) framework.11
3. Form a stakeholder group representing appropriate clinician, policymaker, and patient perspectives.
4. Expand the list of evidence gaps based on stakeholder input.
5. Perform an updated review of published literature since the last CER (search last updated in December 2011) and a horizon scan for recently published and ongoing studies that may address the evidence gaps, but which are not included in the current CER.
6. Solicit stakeholder prioritization of the identified research gaps based on the updated literature review.
7. Determine the most appropriate study designs for the highest priority research areas.12

## Analytic Framework

Figure 1 depicts the Key Questions within the context of the population, interventions, comparators of interest, outcomes, timing, and settings (PICOTS). In general, the figure shows that KQ 1 focuses on the population of women presenting with ST elevation myocardial infarction. KQ 1a considers the effectiveness of optimal medical therapy (i.e., fibrinolytics) versus percutaneous coronary intervention (PCI) on clinical outcomes (i.e., nonfatal MI, death, stroke, repeat revascularization, unstable angina, heart failure, repeat hospitalization, length of hospital stay, angina relief, quality of life, or cognitive effects). KQ 1b considers the modifiers of effectiveness (i.e., age, race, demographic and socioeconomic risk factors; coronary disease risk factors; angiography-specific factors; and hospital characteristics). KQ 1c considers the safety concerns associated with each treatment strategy (e.g., adverse drug reactions, radiation exposure, access site complications, renal dysfunction, anaphylaxis, arrhythmias, stent thrombosis, bleeding, infections). KQ 2 focuses on the population of women presenting with unstable angina or non-ST elevation myocardial infarction. KQ 2a considers the effectiveness of initial conservative therapy versus early invasive therapy (PCI or CABG) on clinical outcomes. KQ 2b considers the associated modifiers of effectiveness, and KQ 2c considers the associated safety concerns. KQ 3 focuses on the population of women presenting with stable angina or unstable angina. KQ 3a considers the effectiveness of two treatment strategies on clinical outcomes: (1) optimal medical therapy versus mechanical revascularization (PCI or CABG) in women with stable angina and (2) PCI versus CABG in women with stable or unstable angina. KQ 3b considers the associated modifiers of effectiveness, and KQ 3c considers the associated safety concerns. The evidence gaps identified for this report fit into the analytic framework as follows: The first gap (with its four subparts) investigates the effects of modifiers on treatment strategies for these three populations and corresponds to KQs 1b, 2b, and 3b; the second, third, and fourth gaps concern the effects of these treatment strategies on the short- and long-term outcomes in all three populations, which corresponds to KQs 1a, 2a, and 3a; and the fifth gap (with its three subparts) looks at adverse effects that may occur due to these treatments and corresponds to KQs 1c, 2c, and 3c.

Figure 1 Analytic framework

Abbreviations: CABG = coronary artery bypass graft; KQ = Key Question; MACE = major adverse cardiovascular events; MI = myocardial infarction; NSTEMI = non-ST elevation myocardial infarction; PCI = percutaneous coronary intervention; STEMI = ST elevation myocardial infarction; UA/NSTEMI = unstable angina/non-ST elevation myocardial infarction

Figure 1 depicts the key questions (KQs) within the context of the PICO (population, interventions, comparators, and outcomes) described elsewhere in this document. In general, the figure shows that KQ 1 focuses on the population of women presenting with ST elevation myocardial infarction. KQ 1a considers the effectiveness of optimal medical therapy (i.e., fibrinolytics) versus percutaneous coronary intervention (PCI) on clinical outcomes (nonfatal MI, death, stroke, repeat revascularization, unstable angina, heart failure, repeat hospitalization, length of hospital stay, angina relief, quality of life, or cognitive effects). KQ 1b considers the modifiers of effectiveness (e.g., age, race, demographic and socioeconomic risk factors; coronary disease risk factors; angiography-specific factors; and hospital characteristics). KQ 1c considers the safety concerns associated with each treatment strategy (e.g., adverse drug reactions, radiation exposure, access site complications, renal dysfunction, anaphylaxis, arrhythmias, stent thrombosis, bleeding, infections). KQ 2 focuses on the population of women presenting with unstable angina or non-ST elevation myocardial infarction. KQ 2a considers the effectiveness of initial conservative therapy versus early invasive therapy (PCI or CABG) on clinical outcomes. KQ 2b considers the associated modifiers of effectiveness, and KQ 2c considers the associated safety concerns. KQ 3 focuses on the population of women presenting with stable angina or unstable angina. KQ 3a considers the effectiveness of two treatment strategies on clinical outcomes: (1) optimal medical therapy versus mechanical revascularization (PCI or CABG) in women with stable angina and (2) PCI versus CABG in women with stable or unstable angina. KQ 3b considers the associated modifiers of effectiveness, and KQ 3c considers the associated safety concerns. The evidence gaps identified for this report fit into the analytic framework as follows: The first gap (with its four subparts) investigates the effects of modifiers on treatment strategies for these three populations and corresponds to KQs 1b, 2b, and 3b; the second, third, and fourth gaps concern the effects of these treatment strategies on the short- and long-term outcomes in all three populations, which corresponds to KQs 1a, 2a, and 3a; and the fifth gap (with its three subparts) looks at adverse effects that may occur due to these treatments and corresponds to KQs 1c, 2c, and 3c.

## Initial List of Research Needs

Results from the 2012 report suggest several evidence gaps for future research. These possibilities are neither exhaustive nor prioritized. The initial list generated by the study authors is provided in Table 2, organized according to the PICO format, with the addition of implementation gaps and methods for evidence synthesis.

Table 2 Initial list of evidence gaps

PICO Element | Evidence Gaps
Population | 1. Is there evidence that the comparative effectiveness of PCI vs. fibrinolysis/supportive therapy in women with STEMI; early invasive vs. initial conservative therapy in women with UA/NSTEMI; or PCI vs. CABG or revascularization vs. optimal medical therapy in women with stable or unstable angina differs by such characteristics as:; a. Age, race, or other demographic and socioeconomic risk factors?; b. Coronary disease risk factors such as diabetes, chronic kidney disease, or other comorbid disease?; c. Angiographic-specific factors (number of diseased vessels, vessel territory stenoses, left ventricular function, access site, or prior PCI or CABG revascularization procedure)?; d. Hospital characteristics (hospital volume, setting, guideline-based treatment protocols)?
Intervention and Comparator | 2 In women presenting with STEMI: What is the effectiveness of PCI vs. fibrinolysis/supportive therapy on intermediate- or long-term clinical outcomes (nonfatal MI, death, stroke, repeat revascularization, recurrent unstable angina, heart failure, repeat hospitalization, length of hospital stay, angina relief, quality of life, or cognitive effects)?; 3 In women presenting with UA/NSTEMI: What is the effectiveness of early invasive (PCI or CABG) vs. initial conservative therapy on short-, intermediate- or long-term clinical outcomes (nonfatal MI, death, stroke, repeat revascularization, recurrent unstable angina, heart failure, repeat hospitalization, length of hospital stay, graft failure, angina relief, quality of life, or cognitive effects)?; 4 In women presenting with stable or unstable angina:; What is the effectiveness of the following treatment strategies on short-, intermediate- or long-term clinical outcomes (nonfatal MI, death, stroke, repeat revascularization, recurrent unstable angina, heart failure, repeat hospitalization, length of hospital stay, graft failure, angina relief, quality of life, or cognitive effects)?; a. Revascularization (PCI or CABG) vs. optimal medical therapy in women with stable angina; b. PCI vs. CABG in women with stable or unstable angina
Outcome | 5 What are the potential harms in women of; a. PCI vs. fibrinolysis/supportive therapy with STEMI?; b. Early invasive vs. initial conservative therapy with UA/NSTEMI?; c. PCI vs. CABG or revascularization vs. optimal medical therapy with stable or unstable angina?

Abbreviations: CABG = coronary artery bypass graft surgery; MI = myocardial infarction; PCI = percutaneous coronary intervention; STEMI = ST elevation myocardial infarction; UA/NSTEMI = unstable angina/non-ST elevation myocardial infarction

## Creation of Stakeholder Group

We selected stakeholders to include researchers involved in some of the primary randomized controlled trials (RCTs) included in the CER, other clinical experts and researchers in the content area, representatives from Federal and nongovernmental funding agencies, representatives from relevant professional societies, health care decisionmakers and policymakers, and representatives from related consumer and patient advocacy groups (Table 3). Within each group, we sought to identify an individual who was either familiar with the clinical area and its current uncertainties, or who brought a specific methodological area of expertise to the workgroup.

Table 3 Stakeholder organizations and roles

Organization | Purpose/Role
National Heart, Lung, and Blood Institute | The National Heart, Lung, and Blood Institute is one of the main funders of potential future studies of the comparative safety and effectiveness of treatment strategies for CAD. It will therefore be important to include their perspective in the prioritization of evidence gaps.
American College of Physicians | The American College of Physicians is the largest group representing internal medicine and its subspecialties. A large portion of the care of patients with CAD is managed by generalists or medicine subspecialists in the office setting and the American College of Physicians will represent this broad group of stakeholders.
American College of Cardiology | The American College of Cardiology is comprised of 39,000 cardiovascular specialists, and is a leader in the formulation of health policy, standards, and guidelines for cardiovascular research.
American Heart Association | The American Heart Association funds clinical, outcomes, and health services research in cardiovascular disease and stroke. They are also a leading advocacy group for advancing science and improving the quality of cardiovascular care.
Office of Research on Women’s Health | The Office of Research on Women’s Health establishes the NIH research agenda for women’s health, co-funds research projects in partnership with NIH Institutes and Centers, and ensures that the NIH policy to include women and minorities in clinical research is followed. It will, therefore, be important to include their perspective in the prioritization of evidence gaps.
Payor | We will be seeking a representative from a private payor in the health insurance industry. Although these payors are not likely not be funders of the future research projects, they would be eventual payors of the treatments recommended by the future research studies; and, therefore, their perspective on the types of studies which would be needed to change their coverage decisions would be helpful.
Patient Advocate | We will identify a patient advocate to represent the research priorities and issues from the patient’s perspective. This person will be oriented to the topic and relevant issues in advance of the discussion so he/she may be an active participant.
Centers for Medicare and Medicaid Services | We will be seeking a representative from the Centers for Medicare and Medicaid Services. Although the Centers for Medicare and Medicaid Services would not be a funder of the future research projects, they would be eventual payors of the treatments recommended by the future research studies; and, therefore, their perspective on the types of studies which would be needed to change their coverage decisions would be helpful.
Society of Thoracic Surgeons | The Society of Thoracic Surgeons comprises over 6,400 surgeons, researchers, and allied health care professionals dedicated to providing the highest quality of care for patients undergoing cardiothoracic surgery and improving surgical outcomes.

Abbreviations: CAD = coronary artery disease; NIH = National Institutes of Health

We were able to recruit representatives from each of these nine groups. A total of 10 (many representing several of the above perspectives) stakeholders were included in our final panel.

Stakeholder input was solicited and received through web-based survey techniques, email, and group discussions via teleconference. Group discussions were moderated by the Evidence-based Practice Center (EPC) investigators to avoid domination of the discussion by any particular group and to ensure that all participants had an equal opportunity to ask questions and express their views. The AHRQ Task Order Officer was a participant in all group teleconferences and was included on all electronic communication with the stakeholder group.

Each potential stakeholder completed a statement of disclosure, was screened for apparent conflicts of interest, and approved by AHRQ prior to the first stakeholder call. Efforts were made to assemble a balanced group of individuals representing a wide range of perspectives.

## Expansion of Research Gaps

We started with the research priorities identified in the CER and input from the stakeholder workgroup during the first call to expand the list of research priorities to include 15 potential evidence gaps (Table 4).

Table 4 Potential Future Research Needs based on the Comparative Effectiveness Review and stakeholder input

PICO Element | Potential Future Research Need
Population | 1. Is there evidence that the comparative effectiveness of PCI vs. fibrinolysis/supportive therapy in women with STEMI; early invasive vs. initial conservative therapy in women with UA/NSTEMI; or PCI vs. CABG or revascularization vs. optimal medical therapy in women with stable or unstable angina differs by such characteristics as: Age, race, or other demographic and socioeconomic risk factors?; 2. Is there evidence that the comparative effectiveness of PCI vs. fibrinolysis/supportive therapy in women with STEMI; early invasive vs. initial conservative therapy in women with UA/NSTEMI; or PCI vs. CABG or revascularization vs. optimal medical therapy in women with stable or unstable angina differs by such characteristics as: Coronary disease risk factors such as diabetes, chronic kidney disease, or other comorbid disease?; 3. Is there evidence that the comparative effectiveness of PCI vs. fibrinolysis/supportive therapy in women with STEMI; early invasive vs. initial conservative therapy in women with UA/NSTEMI; or PCI vs. CABG or revascularization vs. optimal medical therapy in women with stable or unstable angina differs by such characteristics as: Angiographic-specific factors (number of diseased vessels, vessel territory stenoses, left ventricular function, access site, or prior PCI or CABG revascularization procedure)?; 4. Is there evidence that the comparative effectiveness of PCI vs. fibrinolysis/supportive therapy in women with STEMI; early invasive vs. initial conservative therapy in women with UA/NSTEMI; or PCI vs. CABG or revascularization vs. optimal medical therapy in women with stable or unstable angina differs by such characteristics as: Hospital characteristics (hospital volume, setting, guideline-based treatment protocols)?
Intervention and comparator | 5 In women presenting with STEMI: What is the effectiveness of PCI vs. fibrinolysis/supportive therapy on intermediate- or long-term clinical outcomes (nonfatal MI, death, stroke, repeat revascularization, recurrent unstable angina, heart failure, repeat hospitalization, length of hospital stay, angina relief, quality of life, or cognitive effects)?; 6 In women presenting with UA/NSTEMI: What is the effectiveness of early invasive (PCI or CABG) vs. initial conservative therapy on short-, intermediate- or long-term clinical outcomes (nonfatal MI, death, stroke, repeat revascularization, recurrent unstable angina, heart failure, repeat hospitalization, length of hospital stay, graft failure, angina relief, quality of life, or cognitive effects)?; 7 What is the effectiveness of the following treatment strategies on short-, intermediate- or long-term clinical outcomes (nonfatal MI, death, stroke, repeat revascularization, recurrent unstable angina, heart failure, repeat hospitalization, length of hospital stay, graft failure, angina relief, quality of life, or cognitive effects)? Revascularization (PCI or CABG) vs. optimal medical therapy in women with stable angina; 8 What is the effectiveness of the following treatment strategies on short-, intermediate- or long-term clinical outcomes (nonfatal MI, death, stroke, repeat revascularization, recurrent unstable angina, heart failure, repeat hospitalization, length of hospital stay, graft failure, angina relief, quality of life, or cognitive effects)? PCI vs. CABG in women with stable or unstable angina; 9 Are there gender differences in the instruments used to measure functional status, risk factors, comorbidities, etc. associated with CAD?
Outcome | 10 What are the potential harms in women of PCI vs. fibrinolysis/supportive therapy with STEMI?; 11 What are the potential harms in women of early invasive vs. initial conservative therapy with UA/NSTEMI?; 12 What are the potential harms in women of PCI vs. CABG or revascularization vs. optimal medical therapy with stable or unstable angina?; 13 What are the risks, benefits, and costs of different treatments for CAD, stratified by gender?^*^
Implementation gaps | 14 Does patient preference or clinician specialty (primary care, cardiology, cardiothoracic surgery) affect the choice of treatment strategy (medical therapy or type of revascularization)?^*^; 15 Are the patient outcomes from real-world settings or observational registries similar to the findings from randomized clinical trials?^*^

Abbreviations: CABG = coronary artery bypass graft surgery; CAD = coronary artery disease; MI = myocardial infarction; PCI = percutaneous coronary intervention; STEMI = ST elevation myocardial infarction; UA/NSTEMI = unstable angina/non-ST elevation myocardial infarction

* Out-of-scope research topics are in italics.

While many of these research areas were within the scope of the initial review, a few raised by the stakeholder group were outside the scope of this review. These areas may represent important gaps in the knowledge base; however, we are less confident about the current state of the evidence since they were not included in the original report. These “out-of-scope” topics were included in our list, but were specifically noted so that the stakeholders were aware that these areas had not undergone the same level of systematic review and we, therefore, could not provide the same level of detail on the state of current evidence.

We have organized these gaps according to the PICO format and listed them Table 4. The areas determined to be out of scope from the original review are italicized in Table 4.

## Review of the Current Literature

We performed three database searches to identify ongoing and recently published studies relevant to the identified evidence gaps. These searches included:

1. An update of the PubMed^®^, Embase, Cochrane Central Registry of Controlled Trials and Cochrane Database of Systematic Reviews searches used in the original CER to identify relevant literature published since the last search date (12/12/2011).
2. A search of PubMed for relevant systematic reviews and meta-analyses included in our original search and in the update which might address the out of scope evidence gaps.

The exact search strategies used are provided in Appendix A.

Search results were reviewed for applicability to the identified research gaps listed in Table 4. We included articles from each search if they met the following criteria: (1) presents original data or secondary analysis of data from an RCT; (2) includes data for between-category comparisons or treatments of interest (optimal medical therapy alone, PCI plus optimal medical therapy, CABG plus optimal medical therapy); (3) Population includes adult women (≥18 years of age) with CAD and angiographically-proven single- or multiple-vessel disease including STEMI, NSTEMI, and stable angina (4) Data for women are reported as a subgroup; and (5) included outcomes that could be categorized according to our identified list of research priorities. The goal for this literature search was to provide the stakeholders with an idea of which research areas had recent or ongoing literature to address these gaps. Since we did not intend to synthesize this data with the existing report, these articles did not undergo full article abstraction or reconciliation of differences between article reviewers. We did, however, review the full-text of the relevant articles as the reporting of gender-specific outcomes was often not clear at the abstract level.

The search of each database yielded the following list of articles:

Updated PubMed^®^, Embase, Cochrane Central Registry of Controlled Trials and Cochrane Database of Systematic Reviews searches and search of systematic reviews on out of scope topics:

- 613 articles found in updated search
- 46 included as potentially relevant based on abstract screening
- 7 included as relevant based on full text screening

Based on these searches, we created a list of articles and systematic reviews pertaining to the initial list of 15 identified evidence gaps. Relevant literature was identified for four of the 15 initial evidence gaps; that number decreased to three of 14 after the removal of the overarching evidence gap. Of note, the search was unable to identify any articles relevant to the out-of-scope evidence gaps. This document was provided to the stakeholders prior to their final prioritization and is reproduced in Appendix B.

## Research Prioritization

### Process Used

The stakeholders were provided the AHRQ Effective Health Care Program prioritization criteria for Future Research Needs and instructed to use these criteria (potential value criteria [for significant health impact] for addressing the evidence gaps of knowledge, translation, and implementation) as the basis for their decisions regarding research prioritization.

#### Potential Value Criteria

- Potential for new knowledge (research would not be redundant; Question not sufficiently researched, including completed and in-process research; Utility of available evidence limited by changes in practice, e.g., disease detection or evolution in technology)
- Potential for significant health impact on the current and future health status of people with respect to burden of the disease and health outcomes: mortality, morbidity, and quality of life.
- Potential to reduce important inappropriate (or unexplained) variation in clinical practices known to relate to quality of care; potential to resolve controversy or dilemmas in what constitutes appropriate health care; potential to improve decisionmaking for patient or provider, by decreasing uncertainty
- Potential for significant (nontrivial) economic impact related to the costs of health service: to reduce unnecessary or excessive costs; to reduce high costs due to high volume use; to reduce high costs due to high unit cost or aggregate cost. Costs may impact consumers, patients, health care systems, or payers.
- Potential risk from inaction: unintended harms from lack of prioritization of proposed research; opportunity cost of inaction
- Addresses inequities and vulnerable and diverse populations (including issues for patient subgroups); potential to reduce health inequities
- Potential to allow assessment of ethical, legal, social issues pertaining to the condition

#### Probability of Success Criteria

##### Feasibility

- Feasibility of proposed study duration
- Feasibility of proposed study costs (are costs of study reasonable given overall resource constraints)

##### Likelihood

- Likelihood that the study would fill an identified evidence gap
- Likelihood that the study would fill an implementation gap (likely to improve translation of research findings or existing recommendations into clinical practice or identify improved strategies for research translation)
- Likelihood that the study question be answered by a study with low risk of bias?
- Likelihood needed result could be produced in timely manner (efficiency)
- Likelihood that study would provide evidence about both health benefits and potential harms
- Likelihood of change (proposed topic exists within a clinical, consumer, or policymaking context that is likely amenable to evidence-based change)

##### Capacity

- Sufficient research capability and capacity so that the issue can be addressed with confidence
- Utilizes existing resources or builds desired research capacity or decisional support
- Effectively utilizes existing research and knowledge by considering where there is no other research planned or in progress that will answer the research question (nonduplicative)

Participants in our stakeholder group participated in two conference calls, each of which was followed by an online prioritization exercise. The first call (May 2012) was used to introduce the stakeholder group to the project’s objective and to describe the key clinical questions, the original CER report and its findings, and the proposed methods for the prioritization process. During this meeting, the identified research priorities were introduced to the stakeholders, and the group was invited to share feedback regarding additional research priorities. Following this conference call, the stakeholders were invited to perform an initial online ranking of the identified research priorities (including the additional priorities identified by the stakeholder team). This ranking utilized a forced-ranking prioritization method, whereby participants were given 5 votes, which could be allocated to any of the 15 research priorities, with a maximum of 3 votes per item.

Stakeholders then participated in a second conference call (July 2012), during which the Duke EPC team shared the search results for relevant ongoing and recently published studies, as well as the stakeholders’ initial ranking of research priorities results. During this conference call, the majority of the time was dedicated to discussing prioritization, and it was decided to drop one of the evidence gaps. The group felt that this gap (#13 in Table 4) encompassed all of the others and was preventing the true ranking of the 14 remaining gaps. Following this second call, a final online ranking exercise was distributed to the stakeholder group. This exercise utilized the same prioritization method as the first ranking exercise, and produced the final ranked list of research priorities. Research needs were ranked into tiers; only those in the top tier moved on to the final stage of study design development.

### Research Question Development and Research Design Considerations

For the top tier Future Research Needs, we considered advantages and disadvantages of various potential study designs.12 We adapted a conceptual framework for recommending study designs based on our prior report “Future Research Needs for Angiotensin Converting Enzyme Inhibitors or Angiotensin II Receptor Blockers Added to Standard Medical Therapy for Treating Stable Ischemic Heart Disease.”13 Our overall approach to recommending study designs for addressing specific evidence gaps was to emphasize the study design with the least risk of bias, but the greatest likelihood of completion. For areas outside of the original CER scope, we suggested specific study designs that may be appropriate, while remaining cognizant that without a comprehensive systematic review, one cannot determine with certainty the degree to which those evidence gaps have already been addressed. A thorough systematic review may be the most appropriate initial step before further original research is undertaken for the priorities out of scope from the CER. The figure depicting this framework and a discussion of different designs is included in Appendix C.