# Executive Summary

## Background

Cardiovascular disease remains the leading cause of death among women in the United States.1 More than 500,000 women die of cardiovascular disease each year, exceeding the number of deaths in men and the next seven causes of death in women combined. This translates into approximately one death every minute.1,2 This report focuses on women because of the differences in clinical presentation and extent and location of coronary disease on presentation, which affect the treatment options for coronary artery disease (CAD).3–5 Currently available guidelines and systematic reviews provide specific treatment recommendations for women only among a subset of treatment options, and overall assume that treatment options are equally effective for both sexes when gender data are not available. However, women have a worse prognosis than men for manifestations of CAD such as acute myocardial infarction, and some data suggest that women and men may not respond equally to the same treatments. Further, women are more likely than men to experience bleeding complications.6–9

In 2012, a Comparative Effectiveness Review (CER), “Treatment Strategies for Women With Coronary Artery Disease,” attempted to assess the comparative effectiveness of the major treatment options for CAD specifically in women, evaluating these comparisons10:

1. Percutaneous coronary intervention (PCI) versus fibrinolysis or PCI versus conservative/supportive medical management in women with ST elevation myocardial infarction (STEMI)
2. Early invasive versus initial conservative management in women with unstable angina or non-ST elevation myocardial infarction (UA/NSTEMI)
3. PCI versus coronary artery bypass graft surgery (CABG) versus optimal medical therapy in women with stable or unstable angina

Twenty-eight comparative studies contributed evidence about effectiveness, modifiers of effectiveness, or safety for the comparisons above. For women with STEMI, five studies showed a reduction in composite outcomes (primarily death/myocardial infarction (MI)/stroke) at 30 days for PCI over fibrinolysis (odds ratio [OR] 0.50; 95% confidence interval [CI], 0.36 to 0.72; high strength of evidence [SOE]); there was insufficient evidence for assessing outcomes at 1 year. For women with UA/NSTEMI, the included studies, although not showing statistical significance, suggested a benefit of early invasive over initial conservative management for the composite outcome of primarily death/MI at 6 months and (2 studies OR 0.77; 95% CI, 0.28 to 2.12; low SOE; 5 studies OR 0.78; 95% CI, 0.54 to 1.12; low SOE). Evidence suggested a small benefit of initial conservative management at 5 years (2 studies, OR 1.05; 95% CI, 0.81 to 1.35; insufficient SOE); however, with the wide confidence interval crossing 1, and the trend favoring early invasive therapy suggested at earlier time points, we cannot support firm conclusions. For women with stable angina randomized to revascularization (PCI or CABG) or medical therapy, four studies showed a reduction in the composite outcome of death/MI/repeat revascularization at 5 years for revascularization with either PCI (OR 0.64; 95% CI, 0.47 to 0.89; moderate SOE) or CABG (OR 0.56; 95% CI, 0.32 to 0.96; low SOE). For stable and unstable angina trials comparing PCI with CABG, two studies suggested a nonsignificant benefit of PCI in reducing mortality at 30 days (low SOE). At 1 year and beyond, although suggestive of a benefit of CABG for the composite outcomes of death/MI/stroke for women, this finding was not statistically significant and represented wide confidence intervals (low SOE at 1 year and at >2 years).

Five studies assessed modifiers of effectiveness in women due to demographic factors (≥65 or ≥80 years of age) or clinical factors (risk stratification or diabetes). Strength of evidence for modifiers of effectiveness for STEMI, NSTEMI, and stable/unstable angina was insufficient.

Four studies assessed safety outcomes in women: two STEMI studies (PCI vs. fibrinolysis) and two NSTEMI studies (PCI vs. CABG) assessed transfusion rates, incidence of intracranial hemorrhage, and bleeding rates. Strength of evidence for safety outcomes for all the CAD presentations was insufficient.

Given the clinical and economic importance of treating CAD in women, the ongoing investment in CAD research on medical therapy, PCI and CABG, and the remaining areas of uncertainty, we sought to create a prioritized future research agenda that would represent the interests of diverse stakeholders and allow the remaining areas of uncertainty to be addressed.

## Analytic Framework

A number of areas for future research were identified in the CER. We have organized these evidence gaps according to the patient, intervention/comparator, and outcomes (PICO) format. We have categorized these areas for potential future research in the table below (Table A), and mapped them into the Analytic Framework presented in Figure A.

Table A Initial list of evidence gaps

PICO Element | Evidence Gaps
Population | 1. Is there evidence that the comparative effectiveness of PCI vs. fibrinolysis/supportive therapy in women with STEMI; early invasive vs. initial conservative therapy in women with UA/NSTEMI; or PCI vs. CABG or revascularization vs. optimal medical therapy in women with stable or unstable angina differs by such characteristics as:; a. Age, race, or other demographic and socioeconomic risk factors?; b. Coronary disease risk factors such as diabetes, chronic kidney disease, or other comorbid disease?; c. Angiographic-specific factors (number of diseased vessels, vessel territory stenoses, left ventricular function, access site, or prior PCI or CABG revascularization procedure)?; d. Hospital characteristics (hospital volume, setting, guideline-based treatment protocols)?
Intervention and Comparator | 2 In women presenting with STEMI: What is the effectiveness of PCI vs. fibrinolysis/supportive therapy on intermediate- or long-term clinical outcomes (nonfatal MI, death, stroke, repeat revascularization, recurrent unstable angina, heart failure, repeat hospitalization, length of hospital stay, angina relief, quality of life, or cognitive effects)?; 3 In women presenting with UA/NSTEMI: What is the effectiveness of early invasive (PCI or CABG) vs. initial conservative therapy on short-, intermediate- or long-term clinical outcomes (nonfatal MI, death, stroke, repeat revascularization, recurrent unstable angina, heart failure, repeat hospitalization, length of hospital stay, graft failure, angina relief, quality of life, or cognitive effects)?; 4 In women presenting with stable or unstable angina: What is the effectiveness of the following treatment strategies on short-, intermediate- or long-term clinical outcomes (nonfatal MI, death, stroke, repeat revascularization, recurrent unstable angina, heart failure, repeat hospitalization, length of hospital stay, graft failure, angina relief, quality of life, or cognitive effects)?; a. Revascularization (PCI or CABG) vs. optimal medical therapy in women with stable angina; b. PCI vs. CABG in women with stable or unstable angina
Outcome | 5 What are the potential harms in women of:; a. PCI vs. fibrinolysis/supportive therapy with STEMI?; b. Early invasive vs. initial conservative therapy with UA/NSTEMI?; c. PCI vs. CABG or revascularization vs. optimal medical therapy with stable or unstable angina?

Abbreviations: CABG = coronary artery bypass graft surgery; MI = myocardial infarction; PCI = percutaneous coronary intervention; STEMI = ST elevation myocardial infarction; UA/NSTEMI = unstable angina/non-ST elevation myocardial infarction

Figure A Analytic framework

Abbreviations: CABG = coronary artery bypass graft; KQ = Key Question; MACE = major adverse cardiovascular events; MI = myocardial infarction; NSTEMI = non-ST elevation myocardial infarction; PCI = percutaneous coronary intervention; STEMI = ST elevation myocardial infarction; UA/NSTEMI = unstable angina/non-ST elevation myocardial infarction.

Figure A depicts the key questions (KQs) within the context of the PICO (population, interventions, comparators, and outcomes) described elsewhere in this document. In general, the figure shows that KQ 1 focuses on the population of women presenting with ST elevation myocardial infarction. KQ 1a considers the effectiveness of optimal medical therapy (i.e., fibrinolytics) versus percutaneous coronary intervention (PCI) on clinical outcomes (nonfatal MI, death, stroke, repeat revascularization, unstable angina, heart failure, repeat hospitalization, length of hospital stay, angina relief, quality of life, or cognitive effects). KQ 1b considers the modifiers of effectiveness (e.g., age, race, demographic and socioeconomic risk factors; coronary disease risk factors; angiography-specific factors; and hospital characteristics). KQ 1c considers the safety concerns associated with each treatment strategy (e.g., adverse drug reactions, radiation exposure, access site complications, renal dysfunction, anaphylaxis, arrhythmias, stent thrombosis, bleeding, infections). KQ 2 focuses on the population of women presenting with unstable angina or non-ST elevation myocardial infarction. KQ 2a considers the effectiveness of initial conservative therapy versus early invasive therapy (PCI or CABG) on clinical outcomes. KQ 2b considers the associated modifiers of effectiveness, and KQ 2c considers the associated safety concerns. KQ 3 focuses on the population of women presenting with stable angina or unstable angina. KQ 3a considers the effectiveness of two treatment strategies on clinical outcomes: (1) optimal medical therapy versus mechanical revascularization (PCI or CABG) in women with stable angina and (2) PCI versus CABG in women with stable or unstable angina. KQ 3b considers the associated modifiers of effectiveness, and KQ 3c considers the associated safety concerns. The evidence gaps identified for this report fit into the analytic framework as follows: The first gap (with its four subparts) investigates the effects of modifiers on treatment strategies for these three populations and corresponds to KQs 1b, 2b, and 3b; the second, third, and fourth gaps concern the effects of these treatment strategies on the short- and long-term outcomes in all three populations, which corresponds to KQs 1a, 2a, and 3a; and the fifth gap (with its three subparts) looks at adverse effects that may occur due to these treatments and corresponds to KQs 1c, 2c, and 3c.

## Methods

Our approach to identifying evidence gaps, prioritizing future research, and developing recommendations for stakeholders is outlined in the following steps.

1. Develop an analytic framework from the original CER in order to understand the clinical and policy context of the review and its initial list of Future Research Needs.
2. Create an initial list of evidence gaps based on the CER organized according to the PICOframework.11
3. Form a stakeholder group representing appropriate clinician, policymaker, and patient perspectives.
4. Expand the list of evidence gaps based on stakeholder input.
5. Perform an updated review of published literature since the last CER (search last updated in December 2011) and a horizon scan for recently published and ongoing studies that may address the evidence gaps, but which are not included in the current CER.
6. Solicit stakeholder prioritization of the identified research gaps based on the updated literature review.
7. Determine the most appropriate study designs for the highest priority research areas.12

Stakeholders were selected to include a broad range of stakeholder perspectives, including researchers involved in some of the primary randomized controlled trials (RCTs) included in the CER, other clinical experts and researchers in the content area, representatives from Federal and nongovernmental funding agencies, representatives from relevant professional societies, health care decision- and policymakers, and representatives from related consumer and patient advocacy groups. We started with the main research priorities identified in the original CER, and breaking out each sub-section into its own evidence gap resulted in a list of 13 research priorities, including implementation gaps. Based on input from the stakeholder workgroup during the first call, we ultimately expanded the list of research priorities to a total of 15. After the second stakeholder call, it was decided that one of the research priorities needed to be removed since it essentially encompassed all of the other research priorities, thus leaving 14 for the second ranking.

We performed three database searches to identify ongoing and recently published studies relevant to the identified evidence gaps. These included a search of ClinicalTrials.gov, an update of the PubMed, Embase, and Cochrane searches used in the original CER, and a search of PubMed^®^ for relevant systematic reviews that may address the evidence gaps considered out of scope in the original review. Based on these searches, a document was created listing all included articles and clinical trials that might pertain to the initial 15 listed evidence gaps.

The stakeholders were provided with the AHRQ Effective Health Care Program prioritization criteria for Future Research Needs and instructed to use these criteria as the basis for their decisions regarding research prioritization. The stakeholders performed two online rankings of the identified research priorities (including the additional priorities identified by the stakeholder team). This ranking utilized a forced-ranking prioritization method, whereby participants were given 5 votes to allocate to any of the 14–15 research priorities, with a maximum of 3 votes per item.

For the top tier Future Research Needs, we considered potential study designs and their advantages and disadvantages.12 While these proposed methods to address each area are not intended to be restrictive of potential study designs, we comment on each design’s potential benefits or limitations for answering these questions.

## Results

Based on the 2012 CER, “Treatment Strategies for Women With Coronary Artery Disease,”10 and our discussion with stakeholders, we initially identified 15 potential research areas, which were then reduced to 14 areas. The stakeholder voting identified two highest priority areas of future research in each prioritization exercise. The highest priority area from the first prioritization was removed after discussion with the stakeholders, as it was comprehensive of the other research areas and was potentially skewing the rest of the rankings. After the second prioritization, there was just one highest priority area: the second-highest ranked gap from the first prioritization. Initially it was only separated from next-highest ranked gap by 2 points, but after the second prioritization exercise, this separation increased to 8 points and therefore was listed as the sole high priority research area. The results were somewhat different between the two separate prioritization exercises for the middle and lower tiers, as was expected with the removal of the overarching research area; however there was still no great separation between the middle and lower tiers. The research priorities are shown in Table B.

Table B Final ranking of Future Research Needs for treatment strategies for women with CAD

Tier | Question | Score
Top Tier | What is the effectiveness of the following treatment strategies on short-, intermediate- or long-term clinical outcomes (nonfatal MI, death, stroke, repeat revascularization, recurrent unstable angina, heart failure, repeat hospitalization, length of hospital stay, graft failure, angina relief, quality of life, or cognitive effects)? Revascularization (PCI or CABG) vs. optimal medical therapy in women with unstable angina | 13
Middle Tier | Is there evidence that the comparative effectiveness of PCI vs. fibrinolysis/supportive therapy in women with STEMI; early invasive vs. initial conservative therapy in women with UA/NSTEMI; or PCI vs. CABG or revascularization vs. optimal medical therapy in women with stable or unstable angina differs by such characteristics as: Coronary disease risk factors such as diabetes, chronic kidney disease, or other comorbid disease? | 5
Middle Tier | What is the effectiveness of the following treatment strategies on short-, intermediate- or long-term clinical outcomes (nonfatal MI, death, stroke, repeat revascularization, recurrent unstable angina, heart failure, repeat hospitalization, length of hospital stay, graft failure, angina relief, quality of life, or cognitive effects)? PCI vs. CABG in women with stable or unstable angina | 4
Middle Tier | What are the potential harms in women of PCI vs. CABG or revascularization vs. optimal medical therapy with stable or unstable angina? | 4
Middle Tier | Are the patient outcomes from real-world settings or observational registries similar to the findings from randomized clinical trials? * | 4
Middle Tier | Is there evidence that the comparative effectiveness of PCI vs. fibrinolysis/supportive therapy in women with STEMI; early invasive vs. initial conservative therapy in women with UA/NSTEMI; or PCI vs. CABG or revascularization vs. optimal medical therapy in women with stable or unstable angina differs by such characteristics as: Angiographic-specific factors (number of diseased vessels, vessel territory stenoses, left ventricular function, access site, or prior PCI or CABG revascularization procedure)? | 3
Middle Tier | Does patient preference or clinical specialty (primary care, cardiology, cardiothoracic surgery) affect the choice of treatment strategy (medical therapy or type of revascularization)? * | 3
Lower Tier | Is there evidence that the comparative effectiveness of PCI vs. fibrinolysis/supportive therapy in women with STEMI; early invasive vs. initial conservative therapy in women with UA/NSTEMI; or PCI vs. CABG or revascularization vs. optimal medical therapy in women with stable or unstable angina differs by such characteristics as: Age, race, or other demographic and socioeconomic risk factors? | 2
Lower Tier | In women presenting with STEMI: What is the effectiveness of PCI vs. fibrinolysis/supportive therapy on intermediate- or long-term clinical outcomes (nonfatal MI, death, stroke, repeat revascularization, recurrent unstable angina, heart failure, repeat hospitalization, length of hospital stay, angina relief, quality of life, or cognitive effects)? | 2
Lower Tier | In women presenting with UA/NSTEMI: What is the effectiveness of early invasive (PCI or CABG) vs. initial conservative therapy on short-, intermediate- or long-term clinical outcomes (nonfatal MI, death, stroke, repeat revascularization, recurrent unstable angina, heart failure, repeat hospitalization, length of hospital stay, graft failure, angina relief, quality of life, or cognitive effects)? | 2
Lower Tier | Are there gender differences in the instruments used to measure functional status, risk factors, comorbidities, etc. associated with CAD? * | 2
Lower Tier | What are the potential harms in women of early invasive vs. initial conservative therapy with UA/NSTEMI? | 2
Lower Tier | Is there evidence that the comparative effectiveness of PCI vs. fibrinolysis/supportive therapy in women with STEMI; early invasive vs. initial conservative therapy in women with UA/NSTEMI; or PCI vs. CABG or revascularization vs. optimal medical therapy in women with stable or unstable angina differs by such characteristics as: Hospital characteristics (hospital volume, setting, guideline-based treatment protocols)? | 1
Lower Tier | What are the potential harms in women of PCI vs. fibrinolysis/supportive therapy with STEMI? | 1

Abbreviations: CABG = coronary artery bypass graft surgery; CAD = coronary artery disease; MI = myocardial infarction; PCI = percutaneous coronary intervention; STEMI = ST elevation myocardial infarction; UA/NSTEMI = unstable angina/non-ST elevation myocardial infarction

* Out-of-scope research topics are highlighted in italics.

## Discussion

The recommendations for future research prioritization of treatment strategies in this report represents the perspectives of a broad range of stakeholders, including researchers involved in some of the primary RCTs included in the CER, other clinical experts and researchers in the content area, representatives from Federal and nongovernmental funding agencies, representatives from relevant professional societies, health care decisionmakers and policymakers, and representatives from related consumer and patient advocacy groups. The top tier of two research priorities differed slightly between our first and second prioritization exercise due to the removal of one research area. The two areas in the final ranking represent two primary foci: (1) clinical decisionmaking (i.e., the effect of treatment decisions on clinical outcomes); and (2) implementation and generalizability (i.e., the effect of risk factors and comorbid disease on treatment outcomes).

The stakeholder group included a few topics that were out of the scope of the original review, but which are related to issues occurring in actual practice. While the original search strategy may have identified studies addressing these topics, these outcomes were not part of the outcomes of interest in the CER and so there is no available summary of the strength of evidence. The expansion of topics promotes consideration of new areas of research that have not been adequately explored, and this is evidenced by the literature scan in this report, which was unable to identify any articles of relevance to these out-of-scope topics. Nevertheless, the original CER did not comment on the state of current research in these out-of-scope areas, and they should only be promoted with the caveat that the existing literature may already adequately address these areas.

## Conclusions

A workgroup of 10 stakeholders identified the following research area as the highest priority for future research for the comparative effectiveness of treatment strategies for women with CAD.

1. In women presenting with stable or unstable angina: What is the effectiveness of the following treatment strategies on short-, intermediate- or long-term clinical outcomes (i.e., nonfatal MI, death, stroke, repeat revascularization, recurrent unstable angina, heart failure, repeat hospitalization, length of hospital stay, graft failure, angina relief, quality of life, or cognitive effects)? Revascularization (PCI or CABG) versus optimal medical therapy in women with unstable angina
  a. Recommended study design: (preferable) large long-term clinical trial with women-only enrollment or of large enough sample size with stratification of randomization by sex to allow for meaningful sex-based analyses; also possible would be meta-analyses of all existing clinical trials with patient-level data to more accurately describe sex-stratified outcomes

### References

1 Roger VL, Go AS, Lloyd-Jones DM, et al. Heart Disease and Stroke Statistics--2012 update: a report from the American Heart Association. Circulation. Jan. 3. 2012;125(1):e2-e220. [pmid: 22179539].
2 Mosca L, Banka CL, Benjamin EJ, et al. Evidence-based guidelines for cardiovascular disease prevention in women: 2007 update. Circulation. Mar. 20. 2007;115(11):1481-501. [pmid: 17309915].
3 Shaw LJ, Bugiardini R, Merz CN. Women and ischemic heart disease: evolving knowledge. J Am Coll Cardiol. Oct. 20. 2009;54(17):1561-75. [pmid: 19833255].
4 Hochman JS, Tamis JE, Thompson TD, et al. Sex, clinical presentation, and outcome in patients with acute coronary syndromes. Global Use of Strategies to Open Occluded Coronary Arteries in Acute Coronary Syndromes IIb Investigators. N Engl J Med. July. 22. 1999;341(4):226-32. [pmid: 10413734].
5 Berger JS, Elliott L, Gallup D, et al. Sex differences in mortality following acute coronary syndromes. JAMA. Aug. 26. 2009;302(8):874-82. [pmid: 19706861].
6 Mieres JH, Shaw LJ, Arai A, et al. Role of noninvasive testing in the clinical evaluation of women with suspected coronary artery disease: consensus statement from the Cardiac Imaging Committee, Council on Clinical Cardiology, and the Cardiovascular Imaging and Intervention Committee, Council on Cardiovascular Radiology and Intervention, American Heart Association. Circulation. Feb. 8. 2005;111(5):682-96. [pmid: 15687114].
7 Alexander KP, Chen AY, Newby LK, et al. Sex differences in major bleeding with glycoprotein IIb/IIIa inhibitors: results from the CRUSADE (Can Rapid risk stratification of Unstable angina patients Suppress ADverse outcomes with Early implementation of the ACC/AHA guidelines) initiative. Circulation. Sep. 26. 2006;114(13):1380-7. [pmid: 16982940].
8 Pepine CJ. Ischemic heart disease in women: facts and wishful thinking. J Am Coll Cardiol. May. 19. 2004;43(10):1727-30. [pmid: 15145090].
9 Vaccarino V, Abramson JL, Veledar E, et al. Sex differences in hospital mortality after coronary artery bypass surgery: evidence for a higher mortality in younger women. Circulation. Mar. 12. 2002;105(10):1176-81. [pmid: 11889010].
10 Dolor RJ, Melloni C, Chatterjee R, et al. Treatment Strategies for Women With Coronary Artery Disease. Comparative Effectiveness Review No. 66. (Prepared by the Duke Evidence-based Practice Center under Contract No. 290-2007-10066-I.) AHRQ Publication No. 12-EHC070-EF. Rockville, MD. Agency for Healthcare Research and Quality. August. 2012. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
11 Robinson KA, Saldanha IJ, McKoy NA. Development of a framework to identify research gaps from systematic reviews. J Clin Epidemiol. Dec. 2011;64(12):1325-30. [pmid: 21937195].
12 Carey T, Sanders GD, Viswanathan M, et al. Framework for Considering Study Designs for Future Research Needs Methods. Future Research Needs Paper No. 8. (Prepared by the RTI–UNC Evidence-based Practice Center under Contract No. 290-2007-10056-I.). AHRQ Publication No. 12-EHC048-EF. Rockville, MD. Agency for Healthcare Research and Quality. March. 2012. www.effectivehealthcare.ahrq.gov/reports/final.cfm.