# Stakeholders

- Lisa Begg, Dr.P.H., R.N.
  Director of Research Programs
  National Institutes of Health
  Office of Research on Women’s Health
  Bethesda, MD
- Peter Berger, M.D., FACC, FAHA, FSCAI
  Vice-Chairman, Cardiology
  Director, Center for Clinical Studies
  Geisinger Health System
  Danville, PA
- Brenda J. Clark
  Patient Advocate
  Go Red for Women
  American Heart Association
  San Francisco, CA
- Nakela L. Cook, M.D., M.P.H.
  Clinical Medical Officer
  National Heart, Lung and Blood Institute
  Bethesda, MD
- Bernice Hecker, M.D., M.H.A., FACC
  Medical Director, Noridian Administrative
  Services (Medicare contractor)
  Fargo, ND
- Linda Humphrey, M.D., M.P.H.
  Clinical Director
  Evidence-based Synthesis Program
  Portland Veterans Affairs Medical Center
  Portland, OR
- Eugenie Komives, M.D.
  Former Vice President and Sr. Medical Director
  Blue Cross Blue Shield of North Carolina
  Durham, NC
- Lori Mosca, M.D., Ph.D., M.P.H.
  Professor of Medicine
  Director of Preventive Cardiology
  Columbia University Medical Center
  New York–Presbyterian Hospital
  New York, NY
- John Puskas, M.D., M.Sc.
  Professor of Surgery and Associate Chief
  Division of Cardiothoracic Surgery
  Emory University School of Medicine
  Chief of Cardiac Surgery
  Emory University Hospital-Midtown
  Atlanta, GA
- Kimberly Skelding, M.D.
  Director, Cardiovascular Genomics and Cardiovascular Research
  Geisinger Health System
  Danville, PA