# Discussion

The 2012 CER, “Treatment Strategies for Women With Coronary Artery Disease,”10 assessed the comparative effectiveness of treatment options for women with CAD. However, there was low or insufficient evidence from comparative studies to clearly describe short, intermediate, or long-term clinical outcomes of different treatment strategies on women presenting with different forms of coronary artery disease due to the small numbers of women recruited for these clinical trials. Also, there was insufficient evidence to describe the clinical outcomes of different treatment strategies for women with different cardiovascular risk factors, such as diabetes, chronic kidney disease, or other comorbid disease. The recommendations for future research on treatment strategies for women with CAD found in this report represent a broad range of stakeholder perspectives including those of general physicians, physician specialists, researchers, policymakers, and patients. The prioritized areas represent two primary foci: (1) clinical decisionmaking (i.e., the effect of treatment decisions on clinical outcomes); and (2) implementation and generalizability (i.e., the effect of risk factors and comorbid disease on treatment outcomes).

Determining the best treatment strategy in women presenting with different forms of coronary artery disease is critically important given that coronary artery disease is the number one cause of death among women. Future clinical trials to determine long-term clinical outcomes for different presentations of CAD and with different treatment strategies should be designed with recruitment of only women or with recruitment of large enough sample sizes with stratification of randomization by sex to allow for meaningful sex-based analyses. While the most preferable data on clinical outcomes by CAD presentation and treatment strategy would come from new clinical trials, meta-analyses of existing data could contribute to our knowledge in this area. Our review excluded trials that looked for a sex effect yet failed to provide results of women and men by treatment arm. Meta-analyses of existing trials, including those that we excluded, could be performed if patient level data were available in order to stratify treatment and outcomes by sex.

Knowing the influence of different clinical factors on cardiovascular outcomes is important for determining the proper treatment strategy and prognosis of women patients who present with various risk factors and comorbidities. Based on the small number of studies that looked at demographic and clinical factors that influence response to treatment strategies in women, there was insufficient evidence that clinicians can use to determine if certain coronary risk factors should be given greater consideration when deciding on a treatment strategy for women with CAD. It would be difficult to design clinical trials to compare the influence of these different clinical factors on response to treatment strategy. Prospective, observational studies, however, could be designed with standardized and clearly defined treatment strategies and clinical outcomes. These databases could then be used to compare outcomes among women with different clinical risk factors.

Given the limited time the stakeholders have to review the existing evidence, it is also possible that their prioritization represents their general research priorities, rather than the state of evidence for this specific topic. The observation that the top-ranked research priorities focus on the general population of women with CAD, while the majority of research priorities in the lower tier focus on specific populations (women with STEMI or UA/NSTEMI), may be a reflection of this. The CER on this topic noted the lack of evidence due to low numbers of enrollment of women presenting with different forms of CAD, yet not all stakeholders are concerned with these subtypes. It is interesting to note as well that the initial and final top-ranked research priorities were scored so much higher than the next-ranked priority, and that the final top-ranked priority more than doubled its score between the first and second ranking exercises. As AHRQ prepares further prioritization reports, it would be interesting to examine recurrent themes that arise in the top tier of research priorities since they are of direct interest to researchers in the field.

The stakeholder group included a few topics that were out-of-scope for the original review. These topics are related to issues occurring in actual practice, such as the effects of real-world settings and clinician specialty on patient outcomes. While the original search strategy may have identified studies addressing these topics, these outcomes were not part of the outcomes of interest in the CER and so there is no available summary of the strength of evidence. The expansion of topics promotes consideration of new areas of research that have not been adequately explored, and this is evidenced by the literature scan in this report, which was unable to identify any articles of relevance to these out-of-scope topics. Nevertheless, the original CER did not comment on the state of current research in these out-of-scope areas, and they should only be promoted with the caveat that existing literature may already adequately address these areas.