# Conclusions

A workgroup of 10 stakeholders (9 completing the online rankings) identified the following research area as by far the highest priority for future research for the comparative effectiveness of treatment strategies for women with CAD.

1. What is the effectiveness of the following treatment strategies on short-, intermediate- or long-term clinical outcomes (i.e., nonfatal MI, death, stroke, repeat revascularization, recurrent unstable angina, heart failure, repeat hospitalization, length of hospital stay, graft failure, angina relief, quality of life, or cognitive effects)? Revascularization (PCI or CABG) versus optimal medical therapy in women with unstable angina
  a. Recommended study design: (preferable) large long-term clinical trial with women-only enrollment or of large enough sample size with stratification of randomization by sex to allow for meaningful sex-based analyses; also possible would be meta-analyses of all existing clinical trials with patient-level data to more accurately describe sex-stratified outcomes