# Background

Cardiovascular disease remains the leading cause of death among women in the United States.1 More than 500,000 women die of cardiovascular disease each year, exceeding the number of deaths in men and the next seven causes of death in women combined. This translates into approximately one death every minute.1,2 This report focuses on women because of the differences in clinical presentation and coronary anatomy, which affect the treatment options for coronary artery disease (CAD).3–5 Currently available guidelines and systematic reviews provide specific treatment recommendations for women only among a subset of treatment options, and overall assume that treatment options are equally effective for both sexes when gender data are not available. However, women have a worse prognosis than men for manifestations of CAD such as acute myocardial infarction (MI), and some data suggest that women and men do not respond equally to the same treatments. Further, women are more likely than men to experience bleeding complications.6–9

In 2012, a Comparative Effectiveness Review (CER), “Treatment Strategies for Women With Coronary Artery Disease,” attempted to assess the comparative effectiveness of the major treatment options for CAD specifically in women, evaluating these comparisons10:

1. Percutaneous coronary intervention (PCI) versus fibrinolysis or PCI versus conservative/supportive medical management in women with ST elevation myocardial infarction (STEMI)
2. Early invasive versus initial conservative management in women with unstable angina or non-ST elevation myocardial infarction (UA/NSTEMI)
3. PCI versus coronary artery bypass graft surgery (CABG) versus optimal medical therapy in women with stable or unstable angina

The CER addressed the following three Key Questions (KQs):

KQ 1 In women presenting with STEMI:
  a. What is the effectiveness of PCI versus fibrinolysis/supportive therapy on clinical outcomes (e.g., nonfatal MI, death, stroke, repeat revascularization, recurrent unstable angina, heart failure, repeat hospitalization, length of hospital stay, angina relief, quality of life, or cognitive effects)?
  b. Is there evidence that the comparative effectiveness of PCI versus fibrinolysis/supportive therapy varies based on characteristics such as:
    – Age, race, or other demographic and socioeconomic risk factors?
    – Coronary disease risk factors such as diabetes, chronic kidney disease, or other comorbid disease?
    – Angiographic-specific factors (i.e., number of diseased vessels, vessel territory stenoses, left ventricular function, access site, or prior PCI or CABG revascularization procedure)?
    – Hospital characteristics (e.g., hospital volume, setting, guideline-based treatment protocols)?
  c. What are the significant safety concerns associated with each treatment strategy (e.g., adverse drug reactions, radiation exposure, access site complications, renal dysfunction, anaphylaxis, arrhythmias, stent thrombosis, bleeding, infections)?
KQ 2 In women presenting with UA/NSTEMI:
  a. What is the effectiveness of early invasive (PCI or CABG) versus initial conservative therapy on clinical outcomes (e.g., nonfatal MI, death, stroke, repeat revascularization, recurrent unstable angina, heart failure, repeat hospitalization, length of hospital stay, graft failure, angina relief, quality of life, or cognitive effects)?
  b. Is there evidence that the comparative effectiveness of early invasive versus initial conservative therapy varies based on characteristics such as:
    – Age, race, or other demographic and socioeconomic risk factors?
    – Coronary disease risk factors such as diabetes, chronic kidney disease, or other comorbid disease?
    – Angiographic-specific factors (i.e., number of diseased vessels, vessel territory stenoses, left ventricular function, access site, or prior PCI or CABG revascularization procedure)?
    – Hospital characteristics (e.g., hospital volume, setting, guideline-based treatment protocols)?
  c. What are the significant safety concerns associated with each treatment strategy (e.g., adverse drug reactions, radiation exposure, access site complications, renal dysfunction, anaphylaxis, arrhythmias, stent thrombosis, bleeding, infections)?
KQ 3 In women presenting with stable or unstable angina:
  a. What is the effectiveness of the following treatment strategies on clinical outcomes (e.g., nonfatal MI, death, stroke, repeat revascularization, recurrent unstable angina, heart failure, repeat hospitalization, length of hospital stay, graft failure, angina relief, quality of life, or cognitive effects)?
    – Revascularization (PCI or CABG) versus optimal medical therapy in women with stable angina
    – PCI versus CABG in women with stable or unstable angina
  b. Is there evidence that the comparative effectiveness of revascularization versus optimal medical therapy varies based on characteristics such as:
    – Age, race, or other demographic and socioeconomic risk factors?
    – Coronary disease risk factors such as diabetes, chronic kidney disease, or other comorbid disease?
    – Angiographic-specific factors (i.e., number of diseased vessels, vessel territory stenoses, left ventricular function, access site, or prior PCI or CABG revascularization procedure)?
    – CABG-specific factors such as type of surgery performed, cardiopulmonary bypass mode (normothermic versus hypothermic), on-pump versus off-pump, type of cardioplegia used (blood versus crystalloid), or use of saphenous vein grafts, single or bilateral internal mammary artery grafts, or other types of bypass grafts
    – Hospital characteristics (e.g., hospital volume, setting, guideline-based treatment protocols)?
  c. What are the significant safety concerns associated with each treatment strategy (e.g., adverse drug reactions, radiation exposure, access site complications, renal dysfunction, anaphylaxis, arrhythmias, stent thrombosis, bleeding, infections)?

Twenty-eight comparative studies contributed evidence about effectiveness, modifiers of effectiveness, or safety for the comparisons above. For women with STEMI, five studies showed a reduction in composite outcomes (primarily death/MI/stroke) at 30 days for PCI over fibrinolysis (odds ratio [OR] 0.50; 95% confidence interval [CI], 0.36 to 0.72; high strength of evidence [SOE]); there was insufficient evidence for assessing outcomes at 1 year. For women with UA/NSTEMI, the included studies, although not showing statistical significance, suggested a benefit of early invasive over initial conservative management for the composite outcome of primarily death/MI at 6 months and (2 studies OR 0.77; 95% CI, 0.28 to 2.12; low SOE; 5 studies OR 0.78; 95% CI, 0.54 to 1.12; low SOE). Evidence suggested a small benefit of initial conservative management at 5 years (2 studies, OR 1.05; 95% CI, 0.81 to 1.35; insufficient SOE); however, with the wide confidence interval crossing 1, and the trend favoring early invasive therapy suggested at earlier time points, we cannot support firm conclusions. For women with stable angina randomized to revascularization (PCI or CABG) or medical therapy, four studies showed a reduction in the composite outcome of death/MI/repeat revascularization at 5 years for revascularization with either PCI (OR 0.64; 95% CI, 0.47 to 0.89; moderate SOE) or CABG (OR 0.56; 95% CI, 0.32 to 0.96; low SOE). For stable and unstable angina trials comparing PCI with CABG, two studies suggested a nonsignificant benefit of PCI in reducing mortality at 30 days (low SOE). At 1 year and beyond, although suggestive of a benefit of CABG for the composite outcomes of death/MI/stroke for women, this finding was not statistically significant and represented wide confidence intervals (low SOE at 1 year and at >2 years).

Five studies assessed modifiers of effectiveness in women due to demographic factors (≥65 or ≥80 years of age) or clinical factors (risk stratification or diabetes). Strength of evidence for modifiers of effectiveness for STEMI, NSTEMI, and stable/unstable angina was insufficient. Four studies assessed safety outcomes in women: two STEMI studies (PCI vs. fibrinolysis) and two NSTEMI studies (PCI vs. CABG) assessed transfusion rates, incidence of intracranial hemorrhage, and bleeding rates. Strength of evidence for safety outcomes for all the CAD presentations was insufficient.

The weaknesses and shortcomings of the evidence base identified during the review confirmed that more research is needed. Therefore, this Future Research Needs prioritization seeks to review and identify the evidence gaps in the treatment strategies for women with coronary artery disease, and to prioritize the focus and design of future research comparing these modalities. Summary of the evidence and key findings from the review are shown in Table 1.

Table 1 Summary of key findings

Key Question | Strength of Evidence | Conclusions
KQ 1: Women with STEMI (PCI vs. fibrinolysis/supportive therapy) | [underlined: Effectiveness of intervention]; 1. High (women and men) for short-term (30-day) composite outcomes; 2. Insufficient (women and men) for intermediate-term (1-year) composite outcomes; [underlined: Modifiers of effectiveness] Insufficient [underlined: Safety concerns] Insufficient | 7 studies (6 good quality, 1 fair) compared PCI with or without supportive therapy to fibrinolysis or other routine medical care for women with STEMI and contributed evidence about the comparative effectiveness, modifiers of effectiveness, or safety for these interventions. These studies included a total of 4527 patients, of which 1174 (26%) were women.; - [underlined: Effectiveness of interventions:] A meta-analysis of 5 studies (all good quality) reporting 30-day composite outcomes (primarily death/MI/stroke) showed that PCI was better than fibrinolysis in women (OR, 0.50; 95% CI, 0.36 to 0.72) and men (OR, 0.54; 95% CI, 0.42 to 0.70). However, there was insufficient evidence for assessing outcomes at 1 year.; - [underlined: Modifiers of effectiveness:] 2 studies (1 good quality, 1 fair) reported subgroup analyses of demographic or clinical factors in women and included a total of 395 patients, of which 167 (32%) were women. 1 good-quality study evaluated the comparative effectiveness of PCI vs. fibrinolysis in patients <65 years of age and ≥65 and found no differences in in-hospital mortality among the treatment groups. 1 fair-quality study evaluated patients ≥80 years of age with STEMI. The study was limited by a small overall size, and it did not find significant differences in outcomes in patients ≥80 years with STEMI undergoing PCI compared with usual (supportive) medical care.; - [underlined: Safety concerns:] 2 good-quality studies reported safety concerns in women with STEMI and included a total of 1532 patients, of which 367 (24%) were women. 1 study reported a lower nadir hematocrit in women receiving PCI vs. fibrinolysis but no statistically significant differences in the requirement for blood transfusion. Another study reported the proportion of women with intracranial hemorrhage in women who received PCI vs. accelerated t-PA (0% vs. 4.1%). No studies systematically reported radiation exposure, contrast reactions, access site complications, or stent thrombosis in women with STEMI undergoing PCI.
KQ 2: Women with UA/NSTEMI (early invasive vs. initial conservative) | [underlined: Effectiveness of interventions]; 1. Low (women) and high (men) for short-term (6-month) composite outcomes; 2. Low (women and men) for intermediate-term (1-year) composite outcomes; 3. Insufficient (women) and low (men) for long-term (5-year) composite outcomes; [underlined: Modifiers of effectiveness] Insufficient [underlined: Safety concerns] Insufficient | 7 studies (6 good quality, 1 fair) compared early invasive (revascularization via PCI or CABG) with initial conservative therapy for women with UA/NSTEMI and contributed evidence about the comparative effectiveness, modifiers of effectiveness, or safety for these interventions. These studies included a total of 17,930 patients, of which 6084 (34%) were women.; - [underlined: Effectiveness of interventions:] A meta-analysis of 2 good-quality studies reporting 6-month composite outcomes (death/MI) suggested a benefit of early invasive compared with initial conservative therapy in women (OR, 0.77; 95% CI, 0.28 to 2.12) that, however, was not statistically significant; early invasive therapy was superior to initial conservative therapy in men at 6 months (OR, 0.65; 95% CI, 0.52 to 0.82; p=0.0002). At 1 year, a meta-analysis of 5 good-quality studies showed that the composite outcome (primarily death/MI) suggested a similar benefit in women who received early invasive therapy (OR, 0.78; 95% CI, 0.54 to 1.12) as well as in men (OR, 0.88; 95% CI, 0.64 to 1.20); however, this was not statistically significant. A meta-analysis of 2 good-quality studies with 5-year followup between early invasive and initial conservative therapy for the composite outcome of death/MI in both sexes suggested a small benefit of initial conservative therapy in women (1.05; 95% CI, 0.81 to 1.35) while suggesting a benefit of early invasive therapy in men (0.91; 95% CI, 0.53 to 1.56). Given the small suggested benefit at 5 years in women, the wide confidence interval crossing 1, and the trend favoring early invasive therapy suggested at earlier time points and across time points in men — we cannot support firm conclusions; - [underlined: Modifiers of effectiveness:] 2 good-quality studies comparing initial conservative medical therapy to early invasive therapy with PCI reported a subgroup analysis by risk stratification and included a total of 4030 patients, of which 1439 (36%) were women. These studies revealed conflicting results—one showed no difference in treatment outcomes in the intermediate- and high-risk groups; the other showed a higher event rate in women in the groups with moderate-to-high risk for thrombolysis in myocardial infarction.; - [underlined: Safety concerns:] 1 good-quality study (2,220 total patients, 757 [34%] women) reported the harms associated with treatment of UA/NSTEMI by sex group but not the rates of events by treatment group. Bleeding in women undergoing PTCA was higher compared with men (adjusted OR, 3.6; 95% CI, 1.6 to 8.3). However, bleeding related to CABG was similar in women and men, with rates of 12.6% and 15%, respectively. No studies systematically reported radiation exposure, contrast reactions, access site complications, stent thrombosis, or infection in women with UA/NSTEMI comparing early invasive with initial conservative therapy.
KQ 3: Strategy 1—women with stable angina (revascularization vs. optimal medical therapy) | [underlined: Effectiveness of interventions]; 1. With the PCI strategy: Moderate (women) and low (men) for long-term (4- to 5-year) composite outcomes; 2. With the CABG strategy: Low (women and men) for long-term (4- to 5-year) composite outcomes; 3. With both types of revascularization: Moderate (women) and low (men) for long-term (4- to 5-year) composite outcomes | 5 studies (all good quality) compared revascularization (PCI or CABG) with optimal medical therapy for women with stable angina and contributed evidence about the comparative effectiveness, modifiers of effectiveness, or safety for these interventions. These studies included a total of 6851 patients, of which 1285 (19%) were women. [underlined: Effectiveness of interventions:] A meta-analysis of 3 good-quality studies with long-term followup on the composite outcomes (death/MI/revascularization) comparing PCI or CABG with optimal medical therapy showed that revascularization was significantly better than optimal medical therapy in women with stable angina (OR, 0.64; 95% CI, 0.47 to 0.89; p=0.008 for PCI strategy trials; OR, 0.56; 95% CI, 0.32 to 0.96; p=0.04 for CABG strategy trials; and OR, 0.59; 95% CI, 0.43 to 0.81; p=0.001 for either PCI or CABG). However, for men with stable angina, the analysis suggested a small benefit for optimal medical therapy when compared with PCI (OR, 1.03; 95% CI, 0.79 to 1.33). This suggested small benefit however has a wide confidence interval crossing 1 and is not supported by additional time periods or by the evidence in women. Analyses suggested a benefit of CABG (OR, 0.62; 95% CI, 0.31 to 1.24) or either PCI or CABG (OR, 0.71; 95% CI, 0.49 to 1.02) in men with stable angina. These findings were not statistically significant and had very wide confidence intervals.
KQ 3: Strategy 2—women with stable/unstable angina (PCI vs. CABG) | [underlined: Effectiveness of interventions]; 1. Low (women and men) for short-term (30-day) composite outcomes; 2. Low (women and men) for intermediate-term (1-year) composite outcomes; 3. Low (women) and high (men) for long-term (>2-year) composite outcomes; [underlined: Modifiers of effectiveness] Insufficient [underlined: Safety concerns] Insufficient | 10 studies (8 good quality, 2 fair) compared PCI with CABG in women with stable/unstable angina and contributed evidence about the comparative effectiveness, modifiers of effectiveness, or safety for these interventions. These studies included a total of 6289 patients, of which 1583 (25%) were women. [underlined: Effectiveness of interventions:] A meta-analysis of 2 good-quality studies reporting a 30-day death outcome showed no statistically significant difference between PCI and CABG in either men or women. The summary odds ratio in women was 0.68 (95% CI, 0.24 to 1.93) and in men was 1.36 (95% CI, 0.44 to 4.24). The odds ratios suggest a possible sex effect, with PCI showing more benefit in women and CABG showing more benefit in men, but the confidence intervals are too wide to support firm conclusions. For 1-year composite outcomes (death/MI/stroke), a meta-analysis of 2 good-quality studies showed lower events in the CABG group for both sexes, but this benefit was not statistically significant. The summary odds ratio in women was 1.30 (95% CI, 0.69 to 2.45) and in men was 1.19 (95% CI, 0.84 to 1.70). For long-term (>2 years) composite outcomes (death/MI/stroke), a meta-analysis of 4 good-quality studies suggested lower events in the CABG group in women (OR, 1.17; 95% CI, 0.90 to 1.54) although again this did not reach statistical significance; however in men, CABG was significantly better than PCI in lowering cardiovascular events (OR, 1.63; 95% CI, 1.20 to 2.23; p=0.002). [underlined: Modifiers of effectiveness:] 1 good-quality study evaluated the comparative effectiveness of PCI vs. CABG in diabetic patients with stable/unstable angina. The survival rate at 7 years was similar in diabetic women from both treatment groups. However in diabetic men, those treated with CABG had higher survival than those treated with PCI. [underlined: Safety concerns:] 1 good-quality study reported harms associated with PCI compared with CABG among women with UA/NSTEMI and found that bleeding associated with PCI was higher in women compared with men (OR, 29.4; 95% CI, 5.3 to 500; p=0.001). No studies systematically reported radiation exposure, contrast reactions, access site complications, stent thrombosis or infection, in women with UA/NSTEMI undergoing PCI or CABG.

Abbreviations: CABG = coronary artery bypass grafting; CI = confidence interval; MI = myocardial infarction; NSTEMI = non-ST elevation myocardial infarction; OR = odds ratio; PCI = percutaneous coronary intervention; SOE = strength of evidence; STEMI = ST elevation myocardial infarction; t-PA = tissue plasminogen activator; UA = unstable angina