# Criteria for Research Prioritization

Appendix C Figure Framework for suggesting study designs for Future Research Needs

Appendix C Figure is a representation of the process used for making recommendations for specific study designs. In general, the study design with the least risk of bias that can also feasibly address specific questions of interest is preferred. Starting with randomized controlled trials (RCTs), the applicability of a particular study design is considered in the context of a specific evidence gap until a reasonable balance is struck between risk of bias and practicality. In decreasing order of preference, study designs considered include RCTs, meta-analyses of RCTs, meta-analyses of observational studies, new observational studies specifically designed to address the evidence gap, analysis of existing observational data, and modeling studies. In some cases, modeling studies can be used to inform the design and evaluation of other study designs.

We explore below in more detail the potential study designs represented in the Figure above and their specific considerations:

## Randomized Controlled Trials (RCTs)

Ideally, all evidence gaps would be filled by conducting effectiveness RCTs that specifically address the area of interest; however, especially for many questions of interest for comparative effectiveness research, RCTs are rarely the most practical option. Considerations include:

- Sample size required for a particular outcome and to include a representative sample of patients: Many outcomes of interest, particularly those involving safety, are relatively uncommon, requiring an inordinately large sample size to achieve adequate power.
- Size of the pool of potential subjects: Some conditions may be relatively uncommon, or the subpopulation of interest relatively small, adversely affecting the sample size.
- Alternatively, comorbidities may be common among patients with the condition in question, creating potential difficulties with inclusion/exclusion criteria for an RCT.
- Duration of followup required: Minimizing loss to followup within the context of a trial, particularly if blinding must be maintained, is both expensive and difficult the longer the duration of followup, but for some outcomes lengthy followup is required.
- Issues with willingness to be randomized: Patient and provider beliefs about effectiveness, side effects, or other factors can make it difficult to recruit subjects into trials for some interventions.
- Generalizability: Inclusion/exclusion criteria often mean that subjects who participate in RCTs rarely reflect the full spectrum of either disease severity or co-morbidity that exists in the real world.

## Meta-Analysis of RCTs

If a new RCT is not feasible, then a meta-analysis of existing RCTs may provide the next most valid answer to the question if studies are available; however, all of the potential difficulties with a new RCT are potential problems with existing RCTs. Given sufficient numbers and quality of existing RCTs, some questions may be addressable through meta-analysis. The main issue is whether data on the variables and outcomes of interest have been collected and reported consistently by enough RCTs to warrant a meta-analysis.

Meta-analysis of RCTs may be particularly appropriate for research gaps outside the scope of the initial CER; however, as highlighted by the authors of the original CER in their discussion of future research needs, this method may also be able answer key questions included in the original CER. Depending on the volume of ongoing research, existing reviews may quickly become out of date, particularly in cardiovascular research. In addition, when insufficient evidence exists for particular key questions, modifying the study inclusion/exclusion criteria from the initial review may allow broader inclusion of studies that can address these research gaps. This may be particularly true when a specific clinical condition, such as hypertension, has significant clinical overlap with related conditions such as ischemic heart disease, peripheral vascular disease, diabetes, chronic kidney disease, or congestive heart failure. When the outcomes of interest are common to all conditions (e.g., medication side effects, quality of life) then meta-analysis across clinical conditions may provide additional useful information. In meta-analyses of clinical trials, clinicians are often interested in examining subset effects, yet study-level analyses can lead to biased assessments and have some limitations in explaining heterogeneity. A meta-analysis of individual patient data offers several advantages for this purpose, but may not always be feasible given the multiple different sources of data and the proprietary nature of industry-sponsored research.

## Meta-Analysis of Observational Studies

If a meta-analysis of RCTs is not feasible, the next most valid and feasible alternative would be a meta-analysis of observational studies. Many of the same issues inherent in meta-analyses of RCTs (both study-level and patient-level data) are also present, including:

- Heterogeneity in study design, inclusion, and exclusion criteria;
- Consistency in variable definitions and collection; and
- Varying duration of followup.

In addition, control of confounding can be especially challenging at the study level. Here, patient-level meta-analysis may be particularly appropriate, since it facilitates adjustment. The main challenge here is accessibility to the appropriate data, which may be difficult, especially with industry-sponsored studies.

## Observational Study—Collection of New Data

If there is not sufficient literature available for a meta-analysis of observational data, then design of a new study would be the next most valid and feasible study design. Ideally, a prospective study with subject recruitment, data collection, and data analysis specifically intended to address the question of interest would be designed and carried out. Challenges to feasibility of a new observational study include:

- Duration of followup and retention: Many of the most important evidence gaps may require data on outcomes over a longer period of time. Subject retention is crucial both to maximize study power and minimize bias to differential dropout, but the resources required to maintain high retention over a long study period are substantial.
- Recruitment: Depending on the outcomes being assessed, participation in an ongoing observational study may be burdensome. Especially for patients treated with already approved treatments and whose clinical care is not affected by participation in a study, assuring maximal recruitment can be difficult. This may be a special problem in some populations with historically low levels of participation in research.

## Observational Study—Analysis of Existing Data

If a new observational study is not feasible, there may be existing data available that address the relevant question. Major issues here include:

- Ease of access to data, particularly proprietary data from industry-sponsored trials or private health plans
- Extracting useful data from administrative or clinical records. ICD-9 (International Classification of Diseases, Ninth Revision) and CPT (Current Procedural Terminology) codes are not sensitive to many relevant factors in a patient’s clinical history, or to disease severity within conditions. Paper records are difficult to abstract because of issues relating to legibility, consistency in diagnostic language, and the human resources required to convert clinical records into useful analytic data. Electronic medical records are more useful, but are not universally used, and systems may not be compatible. For any of these sources, data on the variables of greatest interest may not have been consistently collected.
- Generalizability: Patients enrolled in Medicare, Medicaid, or private health plans may differ in a number of respects, such as income and employment history, that may be relevant, but which may be difficult to adjust for given the available data.

## Modeling

Finally, if none of the above options is feasible, simulation modeling may be able to address some questions. Modeling is particularly helpful for addressing questions that involve very long durations of followup, or options that cannot feasibly be included in an RCT, such as the comparative impact of different screening frequencies on cancer incidence, mortality, and life expectancy. The main limitation here is the availability of appropriate expertise in both modeling and the clinical conditions being studied.