# Table of Research Priorities Linked to Recent Publications and Ongoing Studies

Priority | Details
1 | What is the effectiveness of the following treatment strategies on short-, intermediate- or long-term clinical outcomes (nonfatal MI, death, stroke, repeat revascularization, recurrent unstable angina, heart failure, repeat hospitalization, length of hospital stay, graft failure, angina relief, quality of life, or cognitive effects)? [underlined: Revascularization (PCI or CABG) versus optimal medical therapy in women with stable angina] MEDLINE/Embase/Cochrane: No relevant citations found
2 | Is there evidence that the comparative effectiveness of PCI versus fibrinolysis/supportive therapy in women with STEMI; early invasive versus initial conservative therapy in women with UA/NSTEMI; or PCI versus CABG or revascularization versus optimal medical therapy in women with stable or unstable angina differs by such characteristics as: [underlined: Coronary disease risk factors such as diabetes, chronic kidney disease, or other comorbid disease?] MEDLINE/Embase/Cochrane: No relevant citations found
3 | What is the effectiveness of the following treatment strategies on short-, intermediate- or long-term clinical outcomes (nonfatal MI, death, stroke, repeat revascularization, recurrent unstable angina, heart failure, repeat hospitalization, length of hospital stay, graft failure, angina relief, quality of life, or cognitive effects)? [underlined: PCI versus CABG in women with stable or unstable angina] MEDLINE/Embase/Cochrane: Manfrini O, Eskola M, Karhunen P, et al. Coronary revascularization in patients that become stable. J Am Coll Cardiol. 2012;59(13):E363. Hlatky MA, Boothroyd DB, Bravata DM, et al. Coronary artery bypass surgery compared with percutaneous coronary interventions for multivessel disease: a collaborative analysis of individual patient data from ten randomised trials. Lancet. 2009;373(9670):1190–7.
4 | What are the potential harms in women of PCI versus CABG or revascularization versus optimal medical therapy with stable or unstable angina? MEDLINE/Embase/Cochrane: No relevant citations found
5 | Are the patient outcomes from real-world settings or observational registries similar to the findings from randomized clinical trials? MEDLINE/Embase/Cochrane: No relevant citations found
6 | Is there evidence that the comparative effectiveness of PCI versus fibrinolysis/supportive therapy in women with STEMI; early invasive versus initial conservative therapy in women with UA/NSTEMI; or PCI versus CABG or revascularization versus optimal medical therapy in women with stable or unstable angina differs by such characteristics as: [underlined: Angiographic-specific factors (number of diseased vessels, vessel territory stenoses, left ventricular function, access site, or prior PCI or CABG revascularization procedure)?] MEDLINE/Embase/Cochrane: No relevant citations found
7 | Does patient preference or clinician specialty (primary care, cardiology, cardiothoracic surgery) affect the choice of treatment strategy (medical therapy or type of revascularization)? MEDLINE/Embase/Cochrane: No relevant citations found
8 | Is there evidence that the comparative effectiveness of PCI versus fibrinolysis/supportive therapy in women with STEMI; early invasive versus initial conservative therapy in women with UA/NSTEMI; or PCI versus CABG or revascularization versus optimal medical therapy in women with stable or unstable angina differs by such characteristics as: [underlined: Age, race, or other demographic and socioeconomic risk factors?] MEDLINE/Embase/Cochrane: No relevant citations found
9 | [underlined: In women presenting with ST elevation myocardial infarction (STEMI):] What is the effectiveness of percutaneous coronary intervention (PCI) versus fibrinolysis/supportive therapy on intermediate- or long-term clinical outcomes (nonfatal MI, death, stroke, repeat revascularization, recurrent unstable angina, heart failure, repeat hospitalization, length of hospital stay, angina relief, quality of life, or cognitive effects)? MEDLINE/Embase/Cochrane: Reynolds HR, Forman SA, Tamis-Holland JE, et al. Relationship of female sex to outcomes after myocardial infarction with persistent total occlusion of the infarct artery: analysis of the Occluded Artery Trial (OAT). Am Heart J. 2012;163(3):462–9. Yan AT, Yan RT, Mehta SR, et al. Efficacy of early invasive management postfibrinolysis in men versus women with ST-elevation myocardial infarction: A subgroup analysis from transfer-AMI. Canadian Journal of Cardiology. 2011;27(5):S152–S153.
10 | [underlined: In women presenting with unstable angina or non-ST elevation myocardial infarction (UA/NSTEMI):] What is the effectiveness of early invasive (PCI or CABG) versus initial conservative therapy on short-, intermediate- or long-term clinical outcomes (nonfatal MI, death, stroke, repeat revascularization, recurrent unstable angina, heart failure, repeat hospitalization, length of hospital stay, graft failure, angina relief, quality of life, or cognitive effects)? MEDLINE/Embase/Cochrane: Reynolds HR, Forman SA, Tamis-Holland JE, et al. Relationship of female sex to outcomes after myocardial infarction with persistent total occlusion of the infarct artery: analysis of the Occluded Artery Trial (OAT). Am Heart J. 2012;163(3):462–9. Swahn E, Alfredsson J, Afzal R, et al. Early invasive compared with a selective invasive strategy in women with non-ST-elevation acute coronary syndromes: a substudy of the OASIS 5 trial and a meta-analysis of previous randomized trials. Eur Heart J. 2012;33(1):51–60. Kleopatra K, Muth K, Zahn R, et al. Effect of an invasive strategy on in-hospital outcome and one-year mortality in women with non-ST-elevation myocardial infarction. International Journal of Cardiology. 2011;153(3):291–295.
11 | Are there gender differences in the instruments used to measure functional status, risk factors, comorbidities, etc. associated with CAD? MEDLINE/Embase/Cochrane: No relevant citations found
12 | What are the potential harms in women of early invasive versus initial conservative therapy with UA/NSTEMI? MEDLINE/Embase/Cochrane: No relevant citations found
13 | Is there evidence that the comparative effectiveness of PCI versus fibrinolysis/supportive therapy in women with STEMI; early invasive versus initial conservative therapy in women with UA/NSTEMI; or PCI versus CABG or revascularization versus optimal medical therapy in women with stable or unstable angina differs by such characteristics as: [underlined: Hospital characteristics (hospital volume, setting, guideline-based treatment protocols)?] MEDLINE/Embase/Cochrane: No relevant citations found
14 | What are the potential harms in women of PCI vs. fibrinolysis/supportive therapy with STEMI? MEDLINE/Embase/Cochrane: No relevant citations found
Removed prior to 2^nd^ survey
N/A | What are the risks, benefits, and costs of different treatments for CAD, stratified by gender? MEDLINE/Embase/Cochrane: Cohen DJ, Lavelle TA, Van Hout B, et al. Economic outcomes of percutaneous coronary intervention with drug-eluting stents versus bypass surgery for patients with left main or three-vessel coronary artery disease: One-year results from the SYNTAX trial. Catheterization and Cardiovascular Interventions. 2012;79(2):198–209.