# Exact Search Strings

The exact search strings used for this project are given below.

## PubMed^®^ Search Strategy (Update of Search Performed for Original CER)

Search Date: June 4, 2012

Set # | Terms
#1 | (“cardiovascular diseases”[MeSH Terms] OR (“cardiovascular”[All Fields] AND “diseases”[All Fields]) OR “cardiovascular diseases”[All Fields]) OR (“heart diseases”[MeSH Terms] OR (“heart”[All Fields] AND “diseases”[All Fields]) OR “heart diseases”[All Fields]) OR (“heart”[MeSH Terms] OR “heart”[All Fields] OR “coronary”[All Fields]) OR cardiovas*[All fields] OR cardiac*[All fields] OR (“myocardium”[MeSH Terms] OR “myocardium”[All Fields] OR “myocardial”[All Fields]) OR (“acute coronary syndrome”[MeSH Terms] OR (“acute”[All Fields] AND “coronary”[All Fields] AND “syndrome”[All Fields]) OR “acute coronary syndrome”[All Fields]) OR (“myocardial infarction”[MeSH Terms] OR (“myocardial”[All Fields] AND “infarction”[All Fields]) OR “myocardial infarction”[All Fields]) OR (“angina, unstable”[MeSH Terms] OR (“angina”[All Fields] AND “unstable”[All Fields]) OR “unstable angina”[All Fields] OR (“unstable”[All Fields] AND “angina”[All Fields]))
#2 | “angioplasty, balloon, coronary”[MeSH Terms] OR (“angioplasty”[All Fields] AND “balloon”[All Fields] AND “coronary”[All Fields]) OR “coronary balloon angioplasty”[All Fields] OR (“percutaneous”[All Fields] AND “transluminal”[All Fields] AND “coronary”[All Fields] AND “angioplasty”[All Fields]) OR “percutaneous transluminal coronary angioplasty”[All Fields] OR “ptca”[All Fields] OR percutaneous coronary intervention[All Fields] OR percutaneous coronary interventional[All Fields] OR percutaneous coronary interventions[All Fields] OR PCI[All Fields] OR stent[All Fields] OR stents[All Fields] OR stent*[All Fields] OR “stents”[MeSH Terms] OR (“balloon”[All Fields] AND “angioplasty”[All Fields]) OR “balloon angioplasty”[All Fields] OR “angioplasty, balloon”[MeSH Terms] OR “balloon dilation”[MeSH Terms] OR (“balloon”[All Fields] AND “dilation”[All Fields]) OR “balloon dilation”[All Fields] OR (“balloon”[All Fields] AND “dilatation”[All Fields]) OR “balloon dilatation”[All Fields] OR (“transluminal”[All Fields] AND “angioplasty”[All Fields]) OR “transluminal angioplasty”[All Fields] OR “angioplasty”[MeSH Terms] OR “angioplasty”[All Fields] OR “atherectomy, coronary”[MeSH Terms] OR (“atherectomy”[All Fields] AND “coronary”[All Fields]) OR “coronary atherectomy”[All Fields] OR (“coronary”[All Fields] AND “atherectomy”[All Fields]) OR (“coronary artery bypass”[MeSH Terms] OR (“coronary”[All Fields] AND “artery”[All Fields] AND “bypass”[All Fields]) OR “coronary artery bypass”[All Fields]) OR CABG[All Fields] OR (“coronary artery bypass”[MeSH Terms] OR (“aortocoronary”[All Fields] AND “bypass”[All Fields]) OR “aortocoronary bypass”[All Fields]) OR “coronary revascularization”[All Fields] OR “myocardial revascularization”[All Fields]
#3 | “women”[MeSH Terms] OR “women”[All Fields] OR “woman”[All Fields] OR “female”[MeSH Terms] OR “female”[All Fields] OR “females”[All Fields] OR “sex factors”[MeSH Terms] OR (“sex”[All Fields] AND “factors”[All Fields]) OR “sex factors”[All Fields]
#4 | randomized controlled trial[pt] OR controlled clinical trial[pt] OR randomized[tiab] OR placebo[tiab] OR “clinical trials as topic”[MeSH Terms:noexp] OR randomly[tiab] OR trial[ti]
#5 | #1 AND #2 AND #3 AND #4
#6 | #5 NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp]) NOT Animals[Mesh:noexp]
| Limits: Human, English, Publication Date: 2001- Present

## Embase^®^ Search Strategy (Update of Search Performed for Original CER)

Platform: Embase.com

Search Date: June 4, 2012

Set # | Terms
#1 | ‘cardiovascular disease’/exp OR ‘heart disease’/exp OR ‘heart’/exp OR ‘acute coronary syndrome’/exp OR ‘heart infarction’/exp OR ‘unstable angina pectoris’/exp OR ‘cardiovascular diseases’:ab OR ‘heart diseases’:ab OR heart:ab OR cardiovasc*:ab OR cardiac*:ab OR coronary:ab OR myocardial:ab OR ‘acute coronary syndrome’:ab OR ‘myocardial infarction’:ab OR ‘unstable angina’:ab OR ‘cardiovascular diseases’:ti OR ‘heart diseases’:ti OR heart:ti OR cardiovasc*:ti OR cardiac*:ti OR coronary:ti OR myocardial:ti OR ‘acute coronary syndrome’:ti OR ‘myocardial infarction’:ti OR ‘unstable angina’:ti
#2 | ‘transluminal coronary angioplasty’/exp OR ‘percutaneous coronary intervention’/exp OR ‘stent’/exp OR ‘balloon dilatation’/exp OR ‘percutaneous transluminal angioplasty’/exp OR ‘atherectomy’/exp OR ‘percutaneous transluminal angioplasty’:ti OR ptca:ti OR (‘percutaneous coronary’ NEXT/1 intervention*):ti OR pci:ti OR stent*:ti OR ‘balloon angioplasty’:ti OR ‘balloon dilation’:ti OR ‘balloon dilatation’:ti OR ‘transluminal angioplasty’:ti OR ‘coronary atherectomy’:ti OR ‘percutaneous transluminal angioplasty’:ab OR ptca:ab OR (‘percutaneous coronary’ NEXT/1 intervention*):ab OR pci:ab OR stent*:ab OR ‘balloon angioplasty’:ab OR ‘balloon dilation’:ab OR ‘balloon dilatation’:ab OR ‘transluminal angioplasty’:ab OR ‘coronary atherectomy’:ab OR ‘coronary artery bypass graft’/exp OR ‘heart muscle revascularization’/exp OR ‘coronary artery bypass’:ti OR cabg:ti OR ‘aortocoronary bypass’:ti OR ‘coronary revascularization’:ti OR ‘myocardial revascularization’:ti OR ‘coronary artery bypass’:ab OR cabg:ab OR ‘aortocoronary bypass’:ab OR ‘coronary revascularization’:ab OR ‘myocardial revascularization’:ab OR ‘coronary artery recanalization’/exp
#3 | ‘female’/exp OR female OR women OR woman OR females OR ‘sex difference’/exp
#4 | ‘randomized controlled trial’/exp OR ‘crossover procedure’/exp OR ‘double blind procedure’/exp OR ‘single blind procedure’/exp OR random* OR factorial* OR crossover* OR cross NEAR/1 over* OR placebo* OR doubl* NEAR/1 blind* OR singl* NEAR/1 blind* OR assign* OR allocat* OR volunteer*
#5 | #1 AND #2 AND #3 AND #4
#6 | #5 (AND [embase]/lim NOT [medline]/lim)
| Limits: Human, English, Publication Date: 2001- Present

## Cochrane Search Strategy (Update of Search Performed for Original CER)

Platform: Wiley

Databases searched: Cochrane Central Registry of Controlled Trials and Cochrane Database of Systematic Reviews

Search Date: June 5, 2012

Set # | Terms
#1 | cardiovascular diseases OR heart diseases OR heart OR cardiovas* OR cardiac* OR coronary OR myocardial OR acute coronary syndrome OR myocardial infarction OR unstable angina [in title-abstract-keywords]
#2 | percutaneous transluminal coronary angioplasty OR PTCA OR “percutaneous coronary intervention” OR “percutaneous coronary interventions” OR “percutaneous coronary interventional” OR PCI OR Stent* OR stents OR Balloon angioplasty OR Balloon dilatation OR Balloon dilation OR Transluminal angioplasty OR coronary atherectomy OR Coronary Artery Bypass OR CABG OR aortocoronary bypass OR coronary revascularization OR myocardial revascularization [in title-abstract-keywords]
#3 | women OR woman OR female OR females OR sex factors [in title-abstract-keywords]
#4 | #1 AND #2 AND #3
| Limits: 2001- Present

## PubMed^®^ Search Strategy (Search for Systematic Reviews)

Search Date: June 5, 2012

Set # | Terms
#1 | (“cardiovascular diseases”[MeSH Terms] OR (“cardiovascular”[All Fields] AND “diseases”[All Fields]) OR “cardiovascular diseases”[All Fields]) OR (“heart diseases”[MeSH Terms] OR (“heart”[All Fields] AND “diseases”[All Fields]) OR “heart diseases”[All Fields]) OR (“heart”[MeSH Terms] OR “heart”[All Fields] OR “coronary”[All Fields]) OR cardiovas*[All fields] OR cardiac*[All fields] OR (“myocardium”[MeSH Terms] OR “myocardium”[All Fields] OR “myocardial”[All Fields]) OR (“acute coronary syndrome”[MeSH Terms] OR (“acute”[All Fields] AND “coronary”[All Fields] AND “syndrome”[All Fields]) OR “acute coronary syndrome”[All Fields]) OR (“myocardial infarction”[MeSH Terms] OR (“myocardial”[All Fields] AND “infarction”[All Fields]) OR “myocardial infarction”[All Fields]) OR (“angina, unstable”[MeSH Terms] OR (“angina”[All Fields] AND “unstable”[All Fields]) OR “unstable angina”[All Fields] OR (“unstable”[All Fields] AND “angina”[All Fields]))
#2 | “angioplasty, balloon, coronary”[MeSH Terms] OR (“angioplasty”[All Fields] AND “balloon”[All Fields] AND “coronary”[All Fields]) OR “coronary balloon angioplasty”[All Fields] OR (“percutaneous”[All Fields] AND “transluminal”[All Fields] AND “coronary”[All Fields] AND “angioplasty”[All Fields]) OR “percutaneous transluminal coronary angioplasty”[All Fields] OR “ptca”[All Fields] OR percutaneous coronary intervention[All Fields] OR percutaneous coronary interventional[All Fields] OR percutaneous coronary interventions[All Fields] OR PCI[All Fields] OR stent[All Fields] OR stents[All Fields] OR stent*[All Fields] OR “stents”[MeSH Terms] OR (“balloon”[All Fields] AND “angioplasty”[All Fields]) OR “balloon angioplasty”[All Fields] OR “angioplasty, balloon”[MeSH Terms] OR “balloon dilation”[MeSH Terms] OR (“balloon”[All Fields] AND “dilation”[All Fields]) OR “balloon dilation”[All Fields] OR (“balloon”[All Fields] AND “dilatation”[All Fields]) OR “balloon dilatation”[All Fields] OR (“transluminal”[All Fields] AND “angioplasty”[All Fields]) OR “transluminal angioplasty”[All Fields] OR “angioplasty”[MeSH Terms] OR “angioplasty”[All Fields] OR “atherectomy, coronary”[MeSH Terms] OR (“atherectomy”[All Fields] AND “coronary”[All Fields]) OR “coronary atherectomy”[All Fields] OR (“coronary”[All Fields] AND “atherectomy”[All Fields]) OR (“coronary artery bypass”[MeSH Terms] OR (“coronary”[All Fields] AND “artery”[All Fields] AND “bypass”[All Fields]) OR “coronary artery bypass”[All Fields]) OR CABG[All Fields] OR (“coronary artery bypass”[MeSH Terms] OR (“aortocoronary”[All Fields] AND “bypass”[All Fields]) OR “aortocoronary bypass”[All Fields]) OR “coronary revascularization”[All Fields] OR “myocardial revascularization”[All Fields]
#3 | “women”[MeSH Terms] OR “women”[All Fields] OR “woman”[All Fields] OR “female”[MeSH Terms] OR “female”[All Fields] OR “females”[All Fields] OR “sex factors”[MeSH Terms] OR (“sex”[All Fields] AND “factors”[All Fields]) OR “sex factors”[All Fields] OR gender[tiab]
#4 | “Patient Preference”[Mesh] OR prefer[tiab] OR preferred[tiab] OR preference[tiab] OR “Cardiology”[Mesh] OR cardiology[tiab] OR cardiologist[tiab] OR specialist[tiab] OR specialty[tiab] OR “Primary Health Care”[Mesh] OR “Physicians, Primary Care”[Mesh] OR “primary care”[tiab] cardiothoracic[tiab] OR “Decision Making”[Mesh] OR decision[tiab] OR decide[tiab] OR decided[tiab] OR choice[tiab] OR “Economics”[Mesh] OR “economics” [Subheading] OR cost[tiab] OR costs[tiab]
#5 | #1 AND #2 AND #3 AND #4
#6 | #5 AND systematic[subset] OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[tw] OR “meta-analyses”[tw]) NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp] OR Comment[ptyp]) NOT (animals[mh] NOT humans[mh])
| Limits: English, Publication Date: 2005-