# Abbreviations

AHRQ: Agency for Healthcare Research and Quality
CABG: Coronary artery bypass graft surgery
CAD: Coronary artery disease
CER: Comparative Effectiveness Review
CI: Confidence interval
EPC: Evidence-based Practice Center
KQ: Key Question
MI: Myocardial infarction
NSTEMI: Non-ST elevation myocardial infarction
OR: Odds ratio
PCI: Percutaneous coronary intervention
PICO: Population, interventions, comparators, and outcomes
PICOTS: Population, interventions, comparators, outcomes, timing, and setting
RCT: Randomized controlled trial
SOE: Strength of evidence
STEMI: ST elevation myocardial infarction
UA/NSTEMI: Unstable angina or non-ST elevation myocardial infarction