# Results

Based on the 2012 CER and our discussion with stakeholders, we identified the 19 potential research areas listed in Table 4. Not all areas were considered within the scope of the 2012 CER; these out-of-scope areas are highlighted in italics. Since these areas were out of scope for the original review, it is unclear whether large evidence gaps exist for these areas; however, they were identified and deemed potentially important by the stakeholder panel. With regard to the final stakeholder ranking, all 11 stakeholders participated and ranked the research priorities. The final ranking is listed below in Table 5 and is divided into a top, middle, and lower tier, based on the overall score.

Table 5 Final ranking of Future Research Needs for noninvasive technologies for the diagnosis of CAD in women

Tier | Question | Score
Top Tier | What is the impact of NIT modalities on outcomes beyond diagnostic accuracy (risk stratification, prognostic information, treatment decisions, and clinical outcomes)? | 14
Top Tier | Are women getting the same diagnostic testing as men? Are men over-tested and/or women under-tested? * | 10
Top Tier | What is the comparative accuracy in real world settings? (most of the studies were single center, best-quality/high expertise centers) | 8
Top Tier | Does the comparative accuracy of NITs in women vary based on the pretest probability of CAD of the women undergoing the test? How does the pretest probability of CAD impact the findings on clinical decisionmaking? | 7
Top Tier | What is the comparative effect of NIT modalities on utilization, further testing, and impact on cost? * | 6
Top Tier | Does the comparative accuracy of NITs in women vary based on patient risk profiles? | 5
Top Tier | Is there a sequential order in which NITs should be used for evaluating CAD, i.e. multiple testing or layered-testing strategies? * | 5
Middle Tier | What is the comparative safety and accuracy of functional vs. anatomic NIT modalities? | 4
Middle Tier | What is the comparative safety and accuracy of functional NIT testing strategies with and without imaging? | 4
Middle Tier | How would a better understanding of provider diagnostic ordering patterns and understanding of appropriate use guidelines to support evidence-based decisionmaking impact the use of NITs?^*^ | 3
Middle Tier | Does the comparative accuracy of NITs in women vary based on differing symptomology and timing at presentation? | 2
Middle Tier | Does the comparative accuracy of NITs in women vary based on racial/ethnicity differences? | 2
Middle Tier | What is the value of performing a specific NIT test for the diagnosis of CAD in women, compared with no testing? * | 2
Middle Tier | Does clinician preference, availability, or setting (outpatient vs. chest pain unit of an emergency department) impact NIT use?^*^ | 2
Lower Tier | Does the comparative accuracy of NITs in women vary based on different settings (outpatient, inpatient, emergency room)? * | 1
Lower Tier | Does the comparative accuracy of NITs in women vary based on: body size, heart size, menopausal status, functional status, stress modality? | 1
Lower Tier | How does patient preference of testing factor into decisionmaking? * | 1
Lower Tier | Does the comparative accuracy of NITs in women vary based on age? | 0
Lower Tier | What are the potential harms of NITs? | 0

CAD = coronary artery disease; NIT = noninvasive technology

* Out-of-scope research topics are highlighted in italics.

These final rankings were not significantly changed from the preliminary rankings provided by the stakeholders prior to the second call, although the two evidence gaps related to functional NIT modalities dropped to the middle tier while the gaps related to patient risk profiles and pretest probabilities were raised in priority. Based on the stakeholder-identified top tier, the EPC team discussed potential study designs for each research area—these are listed in Table 6. While the proposed methods to address each area are not intended to be restrictive of potential study designs, this section is intended to discuss the benefits or limitations for each study design for answering these questions.

Table 6 High priority research areas and possible study designs

Research Area | RCT? | Meta-Analysis or Individual Patient Data Analysis Across RCTs? | Meta-Analysis of Observational Studies? | New Observational Study? | Analysis of Existing Data? | Model?
What is the impact of NIT modalities on outcomes beyond diagnostic accuracy (risk stratification, prognostic information, treatment decisions, and clinical outcomes)? | Yes: either need an RCT with long term followup with strategy of NIT’s or need observational study where the test and treatment are tied together. RCT would provide most informative evidence | Maybe: may be appropriate if sufficient studies available, although not identified in initial review | Yes: if the individual patient data is available from the observational studies and the long term outcomes are ascertained the same way for the NITs | Maybe: if RCT is not feasible, then an observational study could explore the evidence gap though without the same fidelity | No: unlikely to help for comparative NIT data as very few comparative studies currently exist with long term clinical outcome findings | Maybe: potential role for helping determine clinically important differences
Are women getting the same diagnostic testing as men? Are men over-tested and/or women under-tested? * | No: most likely not feasible (or ethical) to randomize participants to over-testing or under-testing | Maybe: depends on the data source for testing – observational studies mainly from current administrative datasets have limitations | Yes: if patient level data with indications/clinical comorbidities are captured | Yes: this is feasible with a NIT registry or cohort of patients with similar indications (low-intermediate chest pain) | Maybe: but need the existing data to be comparative and have the features of interest included | Yes: from current observational studies and administrative datasets can build a propensity model to see if women with similar characteristics are getting tested
What is the comparative accuracy in real world settings? (most of the studies were single center, best-quality/high expertise centers) | Maybe: depends on enrollment criteria – question may be more efficiently served with prospective observational registry | No: not unless existing real world registry data available | Maybe: if there is sufficient description of observational studies across broad studies | Yes: national or broad registry for imaging for common indications would allow exploration | Maybe: if broad observational comparative data includes needed patient characteristics | Maybe: potential role for modeling the impact of different rates of outcomes that may be observed outside traditional clinical trials
Does the comparative accuracy of NITs in women vary based on the pretest probability of CAD of the women undergoing the test? How does the pretest probability of CAD impact the findings on clinical decisionmaking? | No: unlikely to randomize to testing schemes based on pretest probability unless the test and strategies defined are different | Maybe: if enough comparative NIT studies had well defined pretest probability of patients | Maybe: if comparative NITs had pretest data, but most don’t and usually same test is not done across spectrum | Yes: could capture in observational study the patient risk and testing performed | No: not enough existing data due to lack of rigorous reporting of symptoms and pretest probability | Maybe: potential role for helping determine clinically important differences
What is the comparative effect of NIT modalities on utilization, further testing, and impact on cost? * | Yes: could be captured as downstream primary or secondary endpoints in RCT for NIT strategies. | Maybe: may be appropriate if sufficient studies available, although not identified in initial review | Yes: if existing observational NIT data have these outcomes reported then can be performed | Yes: can have observational study of downstream utilization and testing | Yes: potentially could do analysis in administrative claims data – would not know impact on decisionmaking | Maybe: potential role in defining clinically or economically meaningful differences
Does the comparative accuracy of NITs in women vary based on patient risk profiles? | No: unlikely to randomize to testing schemes based on pretest probability unless the test and strategies defined are different | Maybe: if enough comparative NIT studies had well defined pretest probability of patients | Maybe: if comparative NITs had pretest data, but most don’t and usually same test is not done across spectrum | Yes: could capture in observational study the patient risk and testing performed | No: not enough existing data due to lack of rigorous reporting of symptoms and pretest probability | Maybe: potential role for helping determine clinically important differences
Is there a sequential order in which NITs should be used for evaluating CAD, i.e. multiple testing or layered-testing strategies? * | Yes: RCT with strategies with multiple tests or algorithms would be useful | Maybe: may be appropriate if sufficient studies available, although not identified in initial review | No: unfortunately – variable use of downstream testing so hard to understand the role of sequential data or tests without specific patient and outcome data | Yes: possibly could design a strategy observational study where the strategy a clinician is using for NITs could be captured at start for an indication | No: limited with regards to multiple difference layered testing strategies and outcomes | Maybe: could use existing claims data to model which patients/ characteristics are associated with layered and sequential testing

CAD = coronary artery disease; NIT= noninvasive technology; RCT = randomized controlled trial

* Out-of-scope research topics are highlighted in italics.