# Methods

## Overview

Our approach to identifying evidence gaps, prioritizing future research, and developing recommendations for stakeholders is outlined in the following steps. Further detail is provided below.

1. Develop an analytic framework from the original CER in order to understand the clinical and policy context of the review and its initial list of Future Research Needs.
2. Create an initial list of evidence gaps based on the CER organized according to the population, interventions, comparators, and outcomes (PICO) framework.3
3. Form a stakeholder group representing appropriate clinician, policymaker, and patient perspectives.
4. Expand the list of evidence gaps based on stakeholder input.
5. Perform an updated review of published literature since the last CER (search last updated in September 2011) and a horizon scan for recently published and ongoing studies that may address the evidence gaps, but which are not included in the current CER.
6. Solicit stakeholder prioritization of the identified research gaps based on the updated literature review.
7. Determine the most appropriate study designs for the highest priority research areas.4

## Analytic Framework

Figure 1 depicts the Key Questions within the context of the population, interventions, comparators of interest, outcomes, timing, and settings (PICOTS). In general, the figure shows that the CER considered the accuracy of one noninvasive diagnostic test (NIT) versus another or versus coronary angiography for diagnosing obstructive and nonobstructive coronary artery disease (CAD) in women with symptoms suspicious for CAD (KQ 1); various possible predictors of diagnostic accuracy (including age, race/ethnicity, body size, heart size, menopausal status, functional status, and stress modality) of the different NITs in this context (KQ 2); whether the use of NITs improves prognostic information, risk stratification, treatment offered, and clinical outcomes (including myocardial infarction, unstable angina, hospitalization, death, revascularization, angina relief, and quality of life in the population of interest) (KQ 3); and whether there are significant safety concerns or risks (including radiation exposure, access site complications, contrast agent-induced nephropathy, nephrogenic systemic fibrosis, anaphylaxis, and arrhythmias) associated with the use of NITs in this context (KQ 4).

Figure 1 Analytic framework

CAD = coronary artery disease; KQ = Key Question; NSF = nephrogenic systemic fibrosis

Note: #1 to #10 represent the evidence gaps outlined in Table 2.

Figure 1 depicts the key questions (KQs) within the context of the PICO (population, interventions, comparators, and outcomes) described elsewhere in this document. In general, the figure shows that the CER will consider the accuracy of one noninvasive diagnostic test (NIT) vs. another or vs. coronary angiography for diagnosing obstructive and nonobstructive coronary artery disease (CAD) in women with symptoms suspicious for CAD (KQ 1, encompassing evidence gaps #1-#8); various possible predictors of diagnostic accuracy (including age, race/ethnicity, body size, heart size, menopausal status, functional status, and stress modality) of the different NITs in this context (KQ 2); whether the use of NITs improves prognostic information, risk stratification, treatment offered, and clinical outcomes (including myocardial infarction, unstable angina, hospitalization, death, revascularization, angina relief, and quality of life in the population of interest) (KQ 3 and evidence gap #10); and whether there are significant safety concerns or risks (including radiation exposure, access site complications, contrast agent-induced nephropathy, nephrogenic systemic fibrosis, anaphylaxis, and arrhythmias) associated with the use of NITs in this context (KQ 4 and evidence gap #9).

## Initial List of Research Needs

Results from the 2012 report suggest several evidence gaps for future research. These possibilities are neither exhaustive nor prioritized. The initial list generated by the study authors is provided in Table 2, organized according to the PICO format, with the addition of implementation gaps and methods for evidence synthesis.

Table 2 Initial list of evidence gaps

PICO Element | Evidence Gaps
Population | 1. Does the comparative accuracy of NITs in women vary based on the pretest probability of CAD of the women undergoing the test? How does the pretest probability of CAD impact the findings on clinical decisionmaking?; 2. Does the comparative accuracy of NITs in women vary based on differing symptomology and timing at presentation?; 3. Does the comparative accuracy of NITs in women vary based on racial/ethnicity differences?; 4. Does the comparative accuracy of NITs in women vary based on patient risk profiles?; 5. Does the comparative accuracy of NITs in women vary based on different settings (outpatient, inpatient, emergency room)?; 6. Does the comparative accuracy of NITs in women vary based on age?
Intervention and comparator | 7 What is the comparative safety and accuracy of functional vs. anatomic NIT modalities?; 8 What is the comparative safety and accuracy of functional NIT testing strategies with and without imaging?
Outcome | 9 What are the potential harms of NITs?; 10 What is the impact of NIT modalities on outcomes beyond diagnostic accuracy (risk stratification, prognostic information, treatment decisions, and clinical outcomes)?

CAD = coronary artery disease; NIT = noninvasive technology

## Creation of Stakeholder Group

We selected stakeholders to include researchers involved in some of the primary randomized controlled trials (RCTs) included in the CER, other clinical experts and researchers in the content area, representatives from Federal and nongovernmental funding agencies, representatives from relevant professional societies, health care decisionmakers and policymakers, and representatives from related consumer and patient advocacy groups (Table 3). Within each group, we sought to identify an individual who was either familiar with the clinical area and its current uncertainties, or who brought a specific methodological area of expertise to the workgroup.

Table 3 Stakeholder organizations and roles

Organization | Purpose/Role
National Heart, Lung, and Blood Institute | The National Heart, Lung, and Blood Institute is one of the main funders of potential future studies of the comparative safety and effectiveness of NITs in patients with suspected CAD. It was important to include their perspective in the prioritization of evidence gaps.
American College of Physicians | The American College of Physicians is the largest group representing internal medicine and its subspecialties. A large portion of the care of patients with CAD is managed by generalists or medicine subspecialists in the office setting and the American College of Physicians represents this broad group of stakeholders.
American College of Cardiology | The American College of Cardiology comprises 39,000 cardiovascular specialists, and is a leader in the formulation of health policy, standards, and guidelines for cardiovascular research.
American Heart Association | The American Heart Association funds clinical, outcome, and health services research on cardiovascular disease and stroke. They are also a leading advocacy group for advancing science and improving the quality of cardiovascular care.
Society of Cardiovascular Computed Tomography | The Society of Cardiovascular Computed Tomography is an international society that addresses all issues pertaining to the field of cardiovascular computed tomography, and develops standards, guidelines, and recommendations for the clinical use of cardiovascular CT. As one of the technologies considered in this report, an expert opinion in this field is invaluable.
Society for Cardiovascular Magnetic Resonance | The Society for Cardiovascular Magnetic Resonance is an international society that provides CMR education, training, standards development, and accreditation. Experts in this field were needed for the CMR testing considered in this report.
American Society of Echocardiography | The American Society of Echocardiography develops guidelines and standards for cardiac ultrasound, one of the noninvasive test modalities considered in this report.
American College of Radiology | The American College of Radiology is committed to making imaging safe, effective and accessible to those who need it. The organization is comprised of radiologists, nuclear medicine physicians, and others; has a strong advocacy component; and provides continuing education for radiology.
Office of Research on Women’s Health | The Office of Research on Women’s Health establishes the NIH research agenda for women’s health, co-funds research projects in partnership with NIH Institutes and Centers, and ensures that the NIH policy to include women and minorities in clinical research is followed. It is important to include their perspective in the prioritization of evidence gaps.
Payor | We sought a representative from a private payor in the health insurance industry. Although these payors are not likely to be funders of future research projects, they will be eventual payors of the treatments recommended by the future research studies; and, therefore, their perspective on the types of studies needed to change their coverage decisions is helpful.
Patient Advocate | We identified a patient advocate to represent the research priorities and issues from the patient’s perspective. This person was oriented to the topic and relevant issues in advance of the discussion so he/she would be an active participant.
Centers for Medicare and Medicaid Services (CMS) | We sought a representative from the Centers for Medicare and Medicaid Services. Although the Centers for Medicare and Medicaid Services is not likely to be a funder of future research projects, they will be eventual payors of the treatments recommended by the future research studies; and, therefore, their perspective on the types of studies needed to change their coverage decisions is helpful.

CAD = coronary artery disease; CMR = cardiovascular magnetic resonance; CT = computed tomography; NIH = National Institutes of Health; NIT= noninvasive technology

We were able to recruit representatives from each of these twelve groups. A total of 11 (many representing several of the above perspectives) stakeholders were included in our final panel.

Stakeholder input was solicited and received through Web-based survey techniques, email, and group discussions via teleconference. Group discussions were moderated by the Evidence-based Practice Center (EPC) investigators to avoid domination of the discussion by any particular group and to ensure that all participants had an equal opportunity to ask questions and express their views. The AHRQ Task Order Officer was a participant in all group teleconferences and was included on all electronic communication with the stakeholder group.

Each potential stakeholder completed a statement of disclosure, was screened for apparent conflicts of interest, and approved by AHRQ prior to the first stakeholder call. Efforts were made to assemble a balanced group of individuals representing a wide range of perspectives.

## Expansion of Research Gaps

We used the research priorities identified in the CER and input from the stakeholder workgroup during the first call to ultimately expand the list of research priorities to include 19 potential evidence gaps (Table 4).

Table 4 Potential Future Research Needs based on the Comparative Effectiveness Review and stakeholder input

PICO Element | Potential Future Research Need
Population | 1. Does the comparative accuracy of NITs in women vary based on the pretest probability of CAD of the women undergoing the test? How does the pretest probability of CAD impact the findings on clinical decisionmaking?; 2. Does the comparative accuracy of NITs in women vary based on differing symptomology and timing at presentation?; 3. Does the comparative accuracy of NITs in women vary based on racial/ethnicity differences?; 4. Does the comparative accuracy of NITs in women vary based on patient risk profiles?; 5. Does the comparative accuracy of NITs in women vary based on different settings (outpatient, inpatient, emergency room)?^*^; 6. Does the comparative accuracy of NITs in women vary based on age?; 7. Does the comparative accuracy of NITs in women vary based on: body size, heart size, menopausal status, functional status, stress modality?
Intervention and comparator | 8 What is the comparative safety and accuracy of functional vs. anatomic NIT modalities?; 9 What is the comparative safety and accuracy of functional NIT testing strategies with and without imaging?; 10 Is there a sequential order in which NITs should be used for evaluating CAD (i.e., multiple testing or layered-testing strategies)?^*^
Outcome | 11 What are the potential harms of NITs?; 12 What is the impact of NIT modalities on outcomes beyond diagnostic accuracy (risk stratification, prognostic information, treatment decisions, and clinical outcomes)?; 13 What is the comparative effect of NIT modalities on utilization, further testing, and impact on cost?^*^; 14 Are women getting the same diagnostic testing as men? Are men over-tested and/or women under-tested?^*^; 15 What is the comparative accuracy in real world settings? (most of the studies were single center, best-quality/high expertise centers); 16 How does patient preference of testing factor into decisionmaking?^*^; 17 What is the value of performing a specific NIT test for the diagnosis of CAD in women, compared with no testing?^*^
Implementation gaps | 18 Does clinician preference, availability, or setting (outpatient vs. chest pain unit of an emergency department) impact NIT use?^*^; 19 How would a better understanding of provider diagnostic ordering patterns and understanding of appropriate use guidelines to support evidence-based decisionmaking impact the use of NITs?^*^

CAD = coronary artery disease; NIT = noninvasive technology

* Out-of-scope research topics are in italics.

While many of these research areas were within the scope of the initial review, several raised by the stakeholder group were outside the scope of this review. These areas may represent important gaps in the knowledge base; however, we are less confident about the current state of the evidence since they were not included in the original report. These “out-of-scope” topics were included in our list, but were specifically noted so that the stakeholders were aware that these areas had not undergone the same level of systematic review and we, therefore, could not provide the same level of detail on the state of current evidence.

We have organized these gaps according to the PICO format and listed them in the table below. The areas determined to be out of scope from the original review are italicized in Table 4.

## Review of Current Literature

We performed three database searches to identify ongoing and recently published studies relevant to the identified evidence gaps. These searches included the following:

1. A search of ClinicalTrials.gov for ongoing studies. This search included the key words “noninvasive” and “coronary artery disease” and NOT “Male” and was limited to open studies received from 12/2010 to 3/2012.
2. An update of the PubMed^®^, Embase, Cochrane Central Registry of Controlled Trials and Cochrane Database of Systematic Reviews searches used in the original CER to identify relevant literature published since the last search date (9/12/2011).
3. A search of PubMed for relevant systematic reviews and meta-analyses included in our original search and in the update which might address the out of scope evidence gaps.

The exact search strategies used are provided in Appendix A.

Search results were reviewed for applicability to the identified research gaps listed in Table 4. We included articles from each search if they met the following criteria: (1) presents original data or secondary analysis of data from an RCT, prospective or retrospective observational study, or registry (2) includes data for an NIT of interest (ECG, ECHO, SPECT/PET, CMR, or CTA); (3) population includes women with chest pain syndrome; results are reported separately for symptomatic group; (4) population includes women not known to have CAD; (5) includes comparison of an NIT to another NIT, or of an NIT to diagnostic cardiac catheterization; (6) data for women are reported as a subgroup; and (7) included outcomes that could be categorized according to our identified list of research priorities. The goal for this literature search was to provide the stakeholders an idea of which research areas had recent or ongoing literature to address these gaps. Since we did not intend to synthesize this data with the existing report, these articles did not undergo full article abstraction or reconciliation of differences between article reviewers. We did however review the full-text of the relevant articles as the reporting of gender-specific outcomes was often not clear at the abstract level.

The search of each database yielded the following list of articles:

ClinicalTrials.gov:

- 21 active protocols submitted since 12/2010
- 5 included as potentially relevant based on screening
- 3 RCTs, 1 observational study, 1 nonrandomized intervention trial
- Sample size: 210 to 1,350 patients

Updated PubMed search and search of systematic reviews on out of scope topics>

- 520 articles found in original search
- 112 included as potentially relevant based on abstract screening
- 8 included as relevant based on full-text screening

Based on these searches, we created a list of articles and clinical trials pertaining to the 19 identified evidence gaps. This document was provided to the stakeholders prior to their final prioritization and is reproduced in Appendix B.

## Research Prioritization

### Process Used

The stakeholders were provided with the AHRQ Effective Health Care Program’s prioritization criteria for Future Research Needs and were instructed to use these criteria (potential value [for significant health impact] for addressing the evidence gaps of knowledge, translation, and implementation, and probability of success) as the basis for their decisions regarding research prioritization.

#### Potential Value Criteria

- Potential for new knowledge: (research would not be redundant; question not sufficiently researched, including completed and in-process research; utility of available evidence limited by changes in practice, e.g., disease detection or evolution in technology)
- Potential for significant health impact on the current and future health status of people with respect to burden of the disease and health outcomes: mortality, morbidity, and quality of life
- Potential to reduce important inappropriate (or unexplained) variation in clinical practices known to relate to quality of care; potential to resolve controversy or dilemmas in what constitutes appropriate health care; potential to improve decisionmaking for patient or provider by decreasing uncertainty
- Potential for significant (nontrivial) economic impact related to the costs of health service: to reduce unnecessary or excessive costs; to reduce high costs due to high volume use; to reduce high costs due to high unit cost or aggregate cost. Costs may impact consumers, patients, health care systems, or payers.
- Potential risk from inaction: unintended harms from lack of prioritization of proposed research; opportunity cost of inaction
- Addresses inequities and vulnerable and diverse populations (including issues for patient subgroups); potential to reduce health inequities
- Potential to allow assessment of ethical, legal, and social issues pertaining to the condition

#### Probability of Success Criteria

##### Feasibility

- Feasibility of proposed study duration
- Feasibility of proposed study costs; are costs of study reasonable, given overall resource constraints?

##### Likelihood

- Likelihood that the study would fill an identified evidence gap
- Likelihood that the study would fill an implementation gap (likely to improve translation of research findings or existing recommendations into clinical practice or identify improved strategies for research translation)
- Likelihood that the study question would be answered by a study with a low risk of bias
- Likelihood that the needed result could be produced in a timely manner (efficiency)
- Likelihood that study would provide evidence about both health benefits and potential harms
- Likelihood of change (proposed topic exists within a clinical, consumer, or policymaking context that is likely amenable to evidence-based change)

##### Capacity

- Sufficient research capability and capacity so that the issue can be addressed with confidence
- Utilizes existing resources or builds desired research capacity or decisional support
- Effectively utilizes existing research and knowledge by considering where there is other research planned or in progress that will answer the research question (nonduplicative)

Participants in our stakeholder group participated in two conference calls, each of which was followed by an online prioritization exercise. The first call (March 2012) was used to introduce the stakeholder group to the project’s objective and to describe the key clinical questions, the original CER report and its findings, and the proposed methods for the prioritization process. During this meeting, the identified research priorities were introduced to the stakeholders, and the group was invited to share feedback regarding additional research priorities. Following this conference call (March 2012), the stakeholders were invited to perform an initial online ranking of the identified research priorities (including the additional priorities identified by the stakeholder team). This ranking utilized a forced-ranking prioritization method, whereby participants were given 7 votes, which could be allocated to any of the 19 research priorities, with a maximum of 3 votes per item.

Stakeholders then participated in a second conference call (April 2012), during which the Duke EPC team shared the search results for relevant ongoing and recently published studies, as well as the stakeholders’ initial ranking of research priorities results. During this conference call, the majority of the time was dedicated to discussing prioritization. Following this second call, a final online ranking exercise was distributed to the stakeholder group. This exercise utilized the same prioritization method as the first ranking exercise, and produced the final ranked list of research priorities. Research needs were ranked into tiers; only those in the top tier moved on to the final stage of study design development.

### Research Question Development and Research Design Considerations

For the top-tier Future Research Needs, we considered advantages and disadvantages of various potential study designs. We adapted a conceptual framework for recommending study designs based on our prior report “Future Research Needs for Angiotensin Converting Enzyme Inhibitors or Angiotensin II Receptor Blockers Added to Standard Medical Therapy for Treating Stable Ischemic Heart Disease.”5 Our overall approach to recommending study designs for addressing specific evidence gaps was to emphasize the study design with the least risk of bias, but the greatest likelihood of completion. For areas outside of the original CER scope, we suggested specific study designs that may be appropriate, while remaining cognizant that without a comprehensive systematic review, one cannot determine with certainty the degree to which those evidence gaps have already been addressed. A thorough systematic review may be the most appropriate initial step before further original research is undertaken for the priorities out of scope from the CER. The figure depicting this framework and a discussion of different designs is included in Appendix C.