# Executive Summary

## Background

Cardiovascular disease is the leading cause of mortality for women in the United States.1 According to the American Heart Association (AHA), approximately one in three female adults have some form of cardiovascular disease. AHA suggests there is evidence showing that women at risk for coronary artery disease (CAD) are less often referred for the appropriate diagnostic test than are men.1 Coronary anatomy and pathology have traditionally been defined and identified by coronary angiography, a procedure that is indicated in patients who have chest pain and are at high risk for CAD. For intermediate-risk patients, clinicians have a wide range of noninvasive technologies (NITs) to choose from that can assess functional status (i.e., ischemia or no ischemia) or visualize anatomic abnormalities (i.e., no CAD, nonobstructive CAD, or obstructive CAD). Functional modalities include stress electrocardiography (ECG); stress echocardiography (ECHO); and stress radionuclide myocardial perfusion imaging, including single-proton emission computed tomography (SPECT) and positron emission tomography (PET). Anatomic modalities include stress myocardial perfusion and wall-motion cardiac magnetic resonance (CMR) imaging and coronary computed tomography angiography (coronary CTA). The comparative safety and accuracy of these NITs in women was uncertain, although substantial data exists for populations combining men and women, and for mixed populations of known and no known CAD.

In 2012, a Comparative Effectiveness Review (CER), “Noninvasive Technologies for the Diagnosis of Coronary Artery Disease in Women,” evaluated the diagnostic accuracy and risks of NITs in women with symptoms suspicious for CAD, including assessing predictors affecting test accuracy, and the ability of NITs to provide risk stratification and prognostic information, inform decisionmaking about treatment options, and affect clinical outcomes.2

A total of 104 comparative studies (110 articles) were included. For women with no known CAD, the summary of accuracy for each NIT modality compared with coronary angiography was ECG (29 studies): sensitivity 62 percent, specificity 68 percent; ECHO (14 studies): sensitivity 79 percent, specificity 83 percent; SPECT (14 studies): sensitivity 81 percent, specificity 78 percent; CMR (5 studies): sensitivity 72 percent, specificity 84 percent; and CTA (5 studies): sensitivity 94 percent, specificity 87 percent. Compared with men evaluated in the same studies, in women ECG and coronary CTA modalities were both less sensitive and less specific. The ECHO and SPECT modalities, although less sensitive, appeared to be more specific in women. The lower specificity of the ECG modality in women was the only statistically significant difference. Strength of evidence was high for ECG, ECHO, and SPECT, and was low for CMR and coronary CTA compared with coronary angiography in women. Eleven comparative studies examined predictors of diagnostic accuracy in women such as postmenopausal status, race/ethnicity, heart size, beta blocker use, and pretest probability; insufficient evidence was available to draw conclusions about predictors that affect accuracy. Eight studies assessed risk stratification and prognostic factors, two studies assessed treatment decisionmaking, and four studies provided comparative clinical outcomes but provided insufficient evidence on the comparative effectiveness of NITs to provide risk stratification, prognostic information, treatment decisionmaking, or impact on clinical outcomes in women. Thirteen comparative studies reported risks. Of these, four studies of coronary CTA showed a higher mean effective radiation dose and attributable risk of cancer incidence in women compared with men; however, radiation safety issues were not discussed in other NIT modalities with radiation exposure. Thus, there was insufficient evidence regarding the comparative risks of various NIT modalities in women.

Given the clinical and economic importance of noninvasive testing for CAD in women, the ongoing investment in NIT research, and the remaining areas of uncertainty, we sought to create a prioritized research agenda that would represent the interests of diverse stakeholders and allow the remaining areas of uncertainty to be addressed.

## Analytic Framework

We mapped the initial list of research needs developed by the CER study authors (Table A) into an analytic framework as depicted in Figure A. The Key Questions from the CER are organized within the context of the population, interventions, comparators of interest, and outcomes (PICO) and are displayed accordingly in the analytic framework.

Table A Initial list of evidence gaps

PICO Element | Evidence Gaps
Population | 1. Does the comparative accuracy of NITs in women vary based on the pretest probability of CAD of the women undergoing the test? How does the pretest probability of CAD impact the findings on clinical decisionmaking?; 2. Does the comparative accuracy of NITs in women vary based on differing symptomology and timing at presentation?; 3. Does the comparative accuracy of NITs in women vary based on racial/ethnicity differences?; 4. Does the comparative accuracy of NITs in women vary based on patient risk profiles?; 5. Does the comparative accuracy of NITs in women vary based on different settings (outpatient, inpatient, emergency room)?; 6. Does the comparative accuracy of NITs in women vary based on age?
Intervention and comparator | 7 What is the comparative safety and accuracy of functional vs. anatomic NIT modalities?; 8 What is the comparative safety and accuracy of functional NIT testing strategies with and without imaging?
Outcome | 9 What are the potential harms of NITs?; 10 What is the impact of NIT modalities on outcomes beyond diagnostic accuracy (risk stratification, prognostic information, treatment decisions, and clinical outcomes)?

CAD = coronary artery disease; NIT = noninvasive technology

Figure A Analytic framework

CAD = coronary artery disease; KQ = Key Question; NSF = nephrogenic systemic fibrosis

Note: #1 to #10 represent the evidence gaps outlined in Table A.

Figure A depicts the key questions (KQs) within the context of the PICO (population, interventions, comparators, and outcomes) described elsewhere in this document. In general, the figure shows that the CER will consider the accuracy of one noninvasive diagnostic test (NIT) vs. another or vs. coronary angiography for diagnosing obstructive and nonobstructive coronary artery disease (CAD) in women with symptoms suspicious for CAD (KQ 1, encompassing evidence gaps #1-#8); various possible predictors of diagnostic accuracy (including age, race/ethnicity, body size, heart size, menopausal status, functional status, and stress modality) of the different NITs in this context (KQ 2); whether the use of NITs improves prognostic information, risk stratification, treatment offered, and clinical outcomes (including myocardial infarction, unstable angina, hospitalization, death, revascularization, angina relief, and quality of life in the population of interest) (KQ 3 and evidence gap #10); and whether there are significant safety concerns or risks (including radiation exposure, access site complications, contrast agent-induced nephropathy, nephrogenic systemic fibrosis, anaphylaxis, and arrhythmias) associated with the use of NITs in this context (KQ 4 and evidence gap #9).

## Methods

Our approach to identifying evidence gaps, prioritizing future research, and developing recommendations for stakeholders is outlined in the following steps:

1. Develop an analytic framework from the original CER in order to understand the clinical and policy context of the review and its initial list of Future Research Needs.
2. Create an initial list of evidence gaps based on the CER organized according to the population, interventions, comparators, and outcomes (PICO) framework.3
3. Form a stakeholder group representing appropriate clinician, policymaker, and patient perspectives.
4. Expand the list of evidence gaps based on stakeholder input.
5. Perform an updated review of published literature since the last CER (search last updated in September 2011) and a horizon scan for recently published and ongoing studies that may address the evidence gaps, but which are not included in the current CER.
6. Solicit stakeholder prioritization of the identified research gaps based on the updated literature review.
7. Determine the most appropriate study designs for the highest priority research areas.

Stakeholders were selected to include a broad range of stakeholder perspectives, including researchers involved in some of the primary randomized controlled trials (RCTs) included in the CER, other clinical experts and researchers in the content area, representatives from Federal and nongovernmental funding agencies, representatives from relevant professional societies, health care decision- and policymakers, and representatives from related consumer and patient advocacy groups. We started with the research priorities identified in the original CER and then, based on input from the stakeholder workgroup during the first call, we ultimately expanded the list of research priorities from a list of 10 to a total of 19.

We performed three database searches to identify ongoing and recently published studies relevant to the identified evidence gaps. These included a search of ClinicalTrials.gov, an update of the PubMed, Embase, and Cochrane searches used in the original CER, and a search of PubMed^®^ for relevant systematic reviews that may address the evidence gaps considered out of scope in the original review. Based on these searches, a document was created listing all included articles and clinical trials that might pertain to the 19 listed evidence gaps.

The stakeholders were provided with the AHRQ Effective Health Care Program “Framework for Considering Study Designs for Future Research Needs,”4 and were instructed to use these criteria as the basis for their decisions regarding research prioritization. The stakeholders performed two online rankings of the identified research priorities (including the additional priorities identified by the stakeholder team). This ranking utilized a forced-ranking prioritization method, whereby participants were given 7 votes to allocate to any of the 19 research priorities, with a maximum of 3 votes per item.

For the top-tier Future Research Needs, we considered potential study designs and their advantages and disadvantages.4 While these proposed methods to address each area are not intended to be restrictive of potential study designs, we comment on each design’s potential benefits or limitations for answering these questions.

## Results

Based on the Comparative Effectiveness Review “Noninvasive Technologies for the Diagnosis of Coronary Artery Disease in Women,”2 and our discussion with stakeholders, we identified 19 potential research areas. The stakeholder voting identified the seven highest priority areas for future research, and these results were consistent over two separate prioritization exercises. The research priorities are shown in Table B.

Table B Final ranking of Future Research Needs for noninvasive technologies for the diagnosis of CAD in women

Tier | Question | Score
Top Tier | What is the impact of NIT modalities on outcomes beyond diagnostic accuracy (risk stratification, prognostic information, treatment decisions, and clinical outcomes)? | 14
Top Tier | Are women getting the same diagnostic testing as men? Are men over-tested and/or women under-tested? * | 10
Top Tier | What is the comparative accuracy in real-world settings? (most of the studies were single center, best-quality/high expertise centers) | 8
Top Tier | Does the comparative accuracy of NITs in women vary based on the pretest probability of CAD of the women undergoing the test? How does the pretest probability of CAD impact the findings on clinical decisionmaking? | 7
Top Tier | What is the comparative effect of NIT modalities on utilization, further testing, and impact on cost? * | 6
Top Tier | Does the comparative accuracy of NITs in women vary based on patient risk profiles? | 5
Top Tier | Is there a sequential order in which NITs should be used for evaluating CAD ( i.e., multiple testing or layered-testing strategies)?^*^ | 5
Middle Tier | What is the comparative safety and accuracy of functional vs. anatomic NIT modalities? | 4
Middle Tier | What is the comparative safety and accuracy of functional NIT testing strategies with and without imaging? | 4
Middle Tier | How would a better understanding of provider diagnostic ordering patterns and understanding of appropriate use guidelines to support evidence-based decisionmaking impact the use of NITs? * | 3
Middle Tier | Does the comparative accuracy of NITs in women vary based on differing symptomology and timing at presentation? | 2
Middle Tier | Does the comparative accuracy of NITs in women vary based on racial/ethnicity differences? | 2
Middle Tier | What is the value of performing a specific NIT test for the diagnosis of CAD in women, compared with no testing? * | 2
Middle Tier | Does clinician preference, availability, or setting (outpatient vs. chest pain unit of an emergency department) impact NIT use?^*^ | 2
Lower Tier | Does the comparative accuracy of NITs in women vary based on different settings (outpatient, inpatient, emergency room)? * | 1
Lower Tier | Does the comparative accuracy of NITs in women vary based on: body size, heart size, menopausal status, functional status, stress modality? | 1
Lower Tier | How does patient preference of testing factor into decisionmaking? * | 1
Lower Tier | Does the comparative accuracy of NITs in women vary based on age? | 0
Lower Tier | What are the potential harms of NITs? | 0

CAD = coronary artery disease; NIT = noninvasive technology

* Out-of-scope research topics are highlighted in italics.

## Discussion

The recommendations for future research prioritization of NITs in this report represents the perspectives of a broad range of stakeholders, including researchers involved in some of the primary RCTs included in the CER, other clinical experts and researchers in the content area, representatives from Federal and nongovernmental funding agencies, representatives from relevant professional societies, health care decision- and policymakers, and representatives from related consumer and patient advocacy groups. The top tier of seven research priorities remained stable between our first and second prioritization exercise. These areas represent three primary foci: (1) clinical decisionmaking (i.e., risk stratification/profiles, pretest probability, prognostic information, treatment decisions,); (2) long-term clinical outcomes (i.e., revascularization and cardiovascular events); and (3) implementation and generalizability (i.e., accuracy and utilization in real world settings, appropriate test ordering, multiple testing or layer-testing strategies).

The stakeholder group identified and prioritized several topics that were out of the scope of the original review, primarily regarding how these tests are being used in actual practice. This suggests a need for more descriptive data to complement trial accuracy data. Although our original search strategy could have identified studies that addressed several of these topics, many of the questions represent ones where the outcomes of interest were not specifically targeted within our review or for which the current published literature largely depends on noncomparative studies. As such, our current systematic review did not allow us to summarize the strength of the available evidence for these questions. The expansion of topics promotes consideration of new areas of research that have not been adequately explored. This is evidenced by the literature scan in this report, which was only able to identify articles or trial records for one of the eight out-of-scope topics. Nevertheless, the original CER did not comment on the state of current research in these out-of-scope areas, and they should only be promoted with the caveat that the existing literature may already adequately address these areas.

## Conclusions

A workgroup of 11 stakeholders identified the following 7 research areas as the highest priority for future research for the comparative effectiveness of NITs for the diagnosis of CAD in women.

1. What is the impact of NIT modalities on outcomes beyond diagnostic accuracy (risk stratification, prognostic information, treatment decisions, and clinical outcomes)?
  a. Recommended study design: large, long-term clinical trial would be preferable, if not possible then an observational study could be informative
2. Are women getting the same diagnostic testing as men? Are men overtested and/or women undertested? (This is an out-of-scope research topic.)
  a. Recommended study design: systematic review of the evidence, potentially followed by either modeling of existing observational studies and administrative datasets to explore whether women with similar characteristics to men are getting tested or development of a new observational study to explore this gap
3. What is the comparative accuracy in real world settings? (most of the studies were single center, best-quality/high-expertise centers)
  a. Recommended study design: systematic review of the evidence, potentially followed by national or broad registry for imaging for common indications exploring findings within real-world settings
4. Does the comparative accuracy of NITs in women vary based on the pretest probability of CAD of the women undergoing the test? How does the pretest probability of CAD impact the findings on clinical decisionmaking?
  a. Recommended study designs: an observational study of patients with varying pretest probabilities of CAD
5. What is the comparative effect of NIT modalities on utilization, further testing, and impact on cost? (This is an out-of-scope research topic.)
  a. Recommended study design: systematic review of the evidence, potentially followed by either a new RCT or observational study if systematic review reveals that this information is not available from analysis of existing data sources
6. Does the comparative accuracy of NITs in women vary based on patient risk profiles?
  a. Recommended study design: an observational study of patients with varying patient risk profiles.
7. Is there a sequential order in which NITs should be used for evaluating CAD, i.e. multiple testing or layered-testing strategies? (This is an out-of-scope research topic.)
  a. Recommended study design: systematic review of the evidence, potentially followed by either new RCT or observational studies with a focus on sequential ordering of NITs.

## References

1 Mieres JH, Shaw LJ, Arai A, et al. Role of noninvasive testing in the clinical evaluation of women with suspected coronary artery disease: Consensus statement from the Cardiac Imaging Committee, Council on Clinical Cardiology, and the Cardiovascular Imaging and Intervention Committee, Council on Cardiovascular Radiology and Intervention, American Heart Association. Circulation. 2005;111(5):682-96. [pmid: 15687114].
2 Dolor RJ, Patel MR, Melloni C, et al. Noninvasive Technologies for the Diagnosis of Coronary Artery Disease in Women. Comparative Effectiveness Review No. 58. (Prepared by the Duke Evidence-based Practice Center under Contract No. 290-2007-10066-I.) AHRQ Publication No. 12-EHC034-EF. Rockville, MD. Agency for Healthcare Research and Quality. June. 2012. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
3 Robinson KA, Saldanha IJ, McKoy NA. Development of a framework to identify research gaps from systematic reviews. J Clin Epidemiol. 2011;64(12):1325-30. [pmid: 21937195].
4 Carey T, Sanders GD, Viswanathan M, et al. Framework for Considering Study Designs for Future Research Needs. Methods Future Research Needs Paper No. 8. (Prepared by the RTI–UNC Evidence-based Practice Center under Contract No. 290-2007-10056-I.) AHRQ Publication No. 12-EHC048-EF. Rockville, MD. Agency for Healthcare Research and Quality. March. 2012. www.effectivehealthcare.ahrq.gov/reports/final.cfm.