# Stakeholders

- Javed Butler, M.D., M.P.H.
  Deputy Chief Science Advisor, American Heart Association
  Professor of Medicine
  Emory University
  Atlanta, GA
- Kavitha M. Chinnaiyan, M.D.
  Medical Director, Noninvasive Cardiology Education
  Beaumont Heart Center
  Royal Oak, MI
- Nakela L. Cook, M.D., M.P.H.
  Clinical Medical Officer
  National Heart, Lung and Blood Institute
  Bethesda, MD
- Paul Heidenreich, M.D., M.S.
  Director, Echocardiography Laboratory
  VA Palo Alto Medical Center
  Professor of Medicine (Cardiovascular)
  Stanford University
  Stanford, CA
- Neil Jensen, M.B.A., M.H.A.
  Director, Cardiology Networks
  United HealthCare
  Edina, MN
- Indira Jevaji, M.D., M.S.L.
  Senior Medical Officer
  Office of Research on Women’s Health
  Bethesda, MD
- Kathryn Kastan, L.C.S.W., M.A.Ed.
  Director, Women’s Health and Advocacy Initiative
  Duke University Medicine
  Durham, NC
- Christopher Kramer, M.D.
  Director, Cardiovascular Imaging Center
  Professor of Radiology and Medicine
  University of Virginia
  Charlottesville, VA
- James K. Min, M.D.
  President, Society of Cardiovascular Computed Tomography
  Associate Professor of Medicine
  Cedars-Sinai Medical Center
  University of California, Los Angeles
  Los Angeles, CA
- Douglas Owens, M.D.
  Director, Center for Primary Care and Outcomes Research
  Professor of Medicine
  Stanford University
  Stanford, CA
- Pamela Woodard, M.D.
  Head, Advanced Cardiac Imaging
  Professor of Medicine
  Washington University
  St. Louis, MO