# Discussion

The 2012 CER, “Noninvasive Technologies for the Diagnosis of Coronary Artery Disease in Women,” provided evidence for the summary sensitivities and specificities of exercise/stress ECG, ECHO, SPECT, CME and coronary CTA compared with coronary angiography. There was limited or insufficient evidence from comparative studies to define the influence of clinical and demographic factors on NIT diagnostic accuracy, risk stratification, prognostic information, treatment decisions, clinical outcomes, and harms in women. The recommendations for future research on NIT found in this report represent a broad range of stakeholder perspectives including those of general physicians, physician specialists, researchers, policymakers, and patients. The prioritized areas represent three primary foci: (1) clinical decisionmaking (i.e. risk stratification/profiles, pretest probability, prognostic information, treatment decisions,); (2) long-term clinical outcomes (i.e. revascularization and cardiovascular events); and (3) implementation and generalizability (i.e. accuracy and utilization in real world settings, appropriate test ordering, multiple testing or layer-testing strategies).

The use of NIT to assist clinicians in decisionmaking is vitally important for determining a woman’s risk profile, prognosis, and treatment of cardiovascular risk factors (hypertension, diabetes, hyperlipidemia, tobacco use, physical inactivity). A comparative study of NITs in women in a long-term clinical trial is preferable, but a more feasible approach could be a prospective observational study of women with varying pretest probabilities and/or risk profiles. The impact of NIT on clinical outcomes in women is an understudied area. Important outcomes include: referral for invasive diagnostic testing (i.e. coronary angiography), revascularization (percutaneous coronary intervention or coronary artery bypass grafting), and cardiovascular events (nonfatal and fatal myocardial infarction, cardiovascular death). Again, a large, long-term clinical trial is the preferred approach, but a prospective, comparative observational study measuring these outcomes over the long-term would strengthen the evidence. Finally, the real-world implementation of NIT is relatively unknown. Whether the diagnostic accuracy of NIT in usual care settings is comparable to the published reports from highly specialized centers needs further study. The appropriate use of NIT in women compared with men, the influence on downstream testing (either multiple tests or layered-testing), and impact on cost is important since the cost of modalities differ. The Government Accountability Office reports that $14.1 billion is spent per year on cardiovascular imaging. A systematic review of the implementation, generalizability, and utilization of NIT in real world settings would need to be performed prior to determining whether future research on administrative databases or registries could be recommended. The original CER showed that very few NIT articles are RCTs; thus, future research involving RCTs is recommended.

Given the limited time the stakeholders have to review the existing evidence, it is also possible that their prioritization represents their general research priorities, rather than the state of evidence for this specific topic. Though it is not the aim of this report, the information is still useful as a representation of topics that are of direct interest to researchers in the field. As AHRQ prepares further prioritization reports, it would be interesting to examine recurrent themes that arise in the top tier of research priorities.

The stakeholder group included several topics that were out of scope for the original review. The expansion of topics promotes consideration of new areas of research that have not been adequately explored; however, the original CER did not comment on the state of current research in these out-of-scope areas, and they should only be promoted with the caveat that existing literature may already adequately address these areas. We identified recent publications on these out-of-scope topics, but we cannot summarize the state of evidence with the same rigor as in-scope topics included in the original CER.