# Conclusions

A workgroup of 11 stakeholders identified the following seven research areas as the highest priority for future research for the comparative effectiveness of NITs for the diagnosis of CAD in women.

1. What is the impact of NIT modalities on outcomes beyond diagnostic accuracy (risk stratification, prognostic information, treatment decisions, and clinical outcomes)?
  a. Recommended study design: large long-term clinical trial would be preferable, if not possible then an observational study could be informative
2. Are women getting the same diagnostic testing as men? Are men over-tested and/or women under-tested? (This is an out-of-scope research topic.)
  a. Recommended study design: systematic review of the evidence, potentially followed by either modeling of existing observational studies and administrative datasets to explore whether women with similar characteristics to men are getting tested or development of a new observational study to explore this gap
3. What is the comparative accuracy in real world settings? (most of the studies were single center, best-quality/high expertise centers)
  a. Recommended study design: systematic review of the evidence, potentially followed by national or broad registry for imaging for common indications exploring findings within real-world settings
4. Does the comparative accuracy of NITs in women vary based on the pretest probability of CAD of the women undergoing the test? How does the pretest probability of CAD impact the findings on clinical decisionmaking?
  a. Recommended study designs: an observational study of patients with varying pretest probabilities of CAD
5. What is the comparative effect of NIT modalities on utilization, further testing, and impact on cost? (This is an out-of-scope research topic.)
  a. Recommended study design: systematic review of the evidence, potentially followed by either a new RCT or observational study if systematic review reveals that this information is not available from analysis of existing data sources
6. Does the comparative accuracy of NITs in women vary based on patient risk profiles?
  a. Recommended study design: an observational study of patients with varying patient risk profiles.
7. Is there a sequential order in which NITs should be used for evaluating CAD, i.e. multiple testing or layered-testing strategies? (This is an out-of-scope research topic.)
  a. Recommended study design: systematic review of the evidence, potentially followed by either new RCT or observational studies with a focus on sequential ordering of NITs.