# Background

Cardiovascular disease is the leading cause of mortality for women in the United States.1 According to the American Heart Association (AHA), approximately one in three female adults have some form of cardiovascular disease. AHA suggests there is evidence showing that women at risk for coronary artery disease (CAD) are less often referred for the appropriate diagnostic test than are men.1 Coronary anatomy and pathology have traditionally been defined and identified by coronary angiography, a procedure that is indicated in patients who have chest pain and are at high risk for CAD. For intermediate-risk patients, clinicians have a wide range of noninvasive technologies (NITs) to choose from that can assess functional status (i.e., ischemia or no ischemia) or visualize anatomic abnormalities (i.e., no CAD, nonobstructive CAD, or obstructive CAD). Functional modalities include stress electrocardiography (ECG); stress echocardiography (ECHO); and stress radionuclide myocardial perfusion imaging, including single-proton emission computed tomography (SPECT) and positron emission tomography (PET). Anatomic modalities include stress myocardial perfusion and wall-motion cardiac magnetic resonance (CMR) imaging and coronary computed tomography angiography (coronary CTA). The comparative safety and accuracy of these NITs in women was uncertain.

In 2012, a Comparative Effectiveness Review, “Noninvasive Technologies for the Diagnosis of Coronary Artery Disease in Women,” evaluated the diagnostic accuracy and risks of NITs in women with symptoms suspicious for CAD, including assessing predictors affecting test accuracy, and the ability of NITs to provide risk stratification and prognostic information, inform decisionmaking about treatment options, and affect clinical outcomes.2 The CER addressed the following four Key Questions (KQs):

KQ 1 What is the accuracy of one NIT in diagnosing obstructive and nonobstructive CAD when compared with another NIT or with coronary angiography in women with symptoms suspicious for CAD?
  - Exercise ECG stress test, including resting ECG technology (e.g., multifunctional cardiogram)
  - Exercise/stress ECHO with or without a contrast agent
  - Exercise/stress radionuclide myocardial perfusion imaging, including SPECT and PET
  - CMR imaging
  - Coronary CTA
KQ 2 What are the predictors of diagnostic accuracy (e.g., age, race/ethnicity, body size, heart size, menopausal status, functional status, stress modality) of different NITs in women?
KQ 3 Is there evidence that the use of NITs (when compared with other NITs or with coronary angiography) in women improves:
  - KQ 3a. Risk stratification/prognostic information?
  - KQ 3b. Decisionmaking regarding treatment options (e.g., revascularization, optimal medical therapy)?
  - KQ 3c. Clinical outcomes (e.g., death, myocardial infarction, unstable angina, hospitalization, revascularization, angina relief, quality of life)?
KQ 4 Are there significant safety concerns/risks (i.e., radiation exposure, access site complications, contrast agent-induced nephropathy, nephrogenic systemic fibrosis, anaphylaxis, arrhythmias) associated with the use of different NITs to diagnose CAD in women with symptoms suspicious for CAD?

A total of 104 comparative studies (110 articles) were included. For women with no known CAD, the summary of accuracy for each NIT modality compared with coronary angiography was ECG (29 studies): sensitivity 62 percent, specificity 68 percent; ECHO (14 studies): sensitivity 79 percent, specificity 83 percent; SPECT (14 studies): sensitivity 81 percent, specificity 78 percent; CMR (5 studies): sensitivity 72 percent, specificity 84 percent; and CTA (5 studies): sensitivity 94 percent, specificity 87 percent. Compared with men evaluated in the same studies, in women ECG and coronary CTA modalities were both less sensitive and less specific. The ECHO and SPECT modalities, although less sensitive, appeared to be more specific in women. The lower specificity of the ECG modality in women was the only statistically significant difference. Strength of evidence was high for ECG, ECHO, and SPECT, and low for CMR and coronary CTA compared with coronary angiography in women. Eleven comparative studies examined predictors of diagnostic accuracy in women such as postmenopausal status, race/ethnicity, heart size, beta blocker use, and pretest probability; insufficient evidence was available to draw conclusions about predictors that affect accuracy. Eight studies assessed risk stratification and prognostic factors, two studies assessed treatment decisionmaking, and four studies provided comparative clinical outcomes. There is insufficient evidence on the comparative effectiveness of NITs to provide risk stratification, prognostic information, treatment decisionmaking, or impact on clinical outcomes in women. Thirteen comparative studies reported risks. Of these, four studies of coronary CTA showed a higher mean effective radiation dose and attributable risk of cancer incidence in women compared with men; however, radiation safety issues were not discussed in other NIT modalities with radiation exposure. Thus, there was insufficient evidence regarding the comparative risks of various NIT modalities in women. Summary of the evidence and findings are shown in Table 1.

Table 1 Summary of key findings

Key Question | Strength of Evidence | Conclusions
KQ 1. Diagnostic accuracy of NITs in women | ECG: High ECHO: High SPECT: High CMR: Low Coronary CTA: Low | 94 studies described the diagnostic accuracy of NITs in comparison to another NIT or coronary angiography in women. Of these 94 studies, 78 studies included sufficient data to estimate the sensitivity and specificity of the NIT compared with coronary angiography. Summary from all studies with no known CAD:; - 41 studies (13 good quality, 22 fair, 6 poor) of exercise ECG showed a summary sensitivity of 62% and specificity of 68%; - 22 studies (8 good quality, 13 fair, 1 poor) of exercise/stress ECHO showed a summary sensitivity of 79% and specificity of 83%; - 30 studies (10 good quality, 15 fair, 5 poor) of exercise/stress radionuclide perfusion imaging (SPECT, PET) showed a summary sensitivity of 81% and specificity of 78%; - 6 studies (5 good quality, 1 fair) of CMR imaging showed a summary sensitivity of 72% and specificity of 84%; - 8 studies (4 good quality, 4 fair) of coronary CTA showed a summary sensitivity of 93% and specificity 77%; Overall, within a given modality, the summary sensitivities and specificities were similar for both types of populations (unknown CAD and mixed known and no known CAD) and for all studies when compared with good-quality studies. For the newer technologies (i.e., coronary CTA and CMR), more studies in women would be needed to support these findings since the 95% CIs were quite wide. In testing for a statistically significant difference between the diagnostic accuracy of testing modalities in women, our analyses determined that for women with no previously known CAD, there were differences between the performance of the available modalities (p < 0.001). The sensitivity of ECHO and SPECT was significantly higher than that of ECG. Specificity of ECG was less than that of CMR (borderline) and of ECHO. In the subset of studies that were good-quality and where there was no known CAD in the included population, our analyses again demonstrated differences between performance of tests (p = 0.006) with the specificity of ECG being less than that of CMR and ECHO. Sensitivity analyses exploring mixed populations of women with known and no known CAD showed no statistically significant difference in the sensitivities and specificities from our primary analysis. An analysis exploring the prevalence of CAD across the different NIT modality studies also showed no statistically significant difference. In addition, there were very few studies (1 SPECT, 1 ECHO, and 3 ECG) that did not complete a coronary angiography in all patients who underwent the NIT; therefore the results are minimized for verification bias. Finally we found no evidence of publication bias across the different modalities in our 4 populations of interest (studies of women with no known CAD, good quality studies of women with no known CAD, studies of women from mixed populations, and good quality studies of women from mixed populations).
KQ 2. Predictors of diagnostic accuracy in women | Insufficient | 11 studies (4 good quality, 5 fair, 2 poor) described diagnostic accuracy, and 9 of these examined predictors of diagnostic accuracy of different NITs in women. Summary:; - The predictors assessed included (1) postmenopausal women ages 55 to 64 (1 study), (2) race/ethnicity (2 studies), (3) heart size (4 studies), (4) pretest probability (3 studies), and (5) use of beta blocker medications (1 study).; - We identified no studies examining the influence of age alone, functional status, or body size on diagnostic accuracy in women.; - In terms of the NIT modality, we found four studies of stress ECHO, six studies of stress ECG, two studies of CMR, and four studies of SPECT that reported these predictors.; - Insufficient evidence was available to draw definitive conclusions about predictors given the small number of studies for each predictor and for each modality, as well as the combination of predictor by modality.
KQ 3. Improving risk stratification, decisionmaking, and outcomes in women | Insufficient | 13 studies (3 good quality, 9 fair, 1 poor) reported prognostic, outcome, or decisionmaking data comparing one NIT with another NIT or with coronary angiography in women with symptoms suspicious for CAD. Summary:; - We found 8 studies assessing risk stratification and prognostic information, 2 studies assessing decisionmaking for treatment options, and 4 studies that provided comparative clinical outcomes.; - There were insufficient data to demonstrate that the use of specific NITs (compared with coronary angiography) routinely provided incremental risk stratification, prognostic information, or other meaningful information to improve decisionmaking and improve patient outcomes.; - Most findings reported in the literature would require significant confirmation and replication in larger studies with women.
KQ 4. Safety concerns | Insufficient | 13 studies (9 good quality, 4 fair) reported data pertinent to safety concerns or risks associated with the use of NITs to diagnose CAD in women with symptoms suspicious for CAD. Summary:; - Safety data were reported on the following modalities: (1) stress ECG (4 studies), (2) ECHO (6 studies), (3) SPECT (3 studies), (4) CMR (2 studies), and (5) coronary CTA (4 studies).; - Data specific to women on access site complications, contrast agent-induced nephropathy, nephrogenic systemic fibrosis, or anaphylaxis associated with NITs were not reported in any of the studies included in this report.; - Other than higher mean effective radiation doses for coronary CTA studies for women compared with men (from 3 out of 4 studies reporting radiation exposure levels), the extant literature does not provide sufficient evidence to conclude whether safety concerns, risks, or radiation exposure associated with different NITs to diagnose CAD in patients with suspected CAD differ significantly between women and men.

CAD = coronary artery disease; CI = confidence interval; CMR = cardiac magnetic resonance; CTA = computed tomography angiography; ECG = exercise/stress electrocardiogram; ECHO = echocardiogram; KQ = Key Question; NIT = noninvasive technology; PET = positron emission tomography; SPECT = single-proton emission computed tomography

The weaknesses and shortcomings of the evidence base identified during the review confirmed that more research is needed. AHRQ supports our Evidence-based Practice Center (EPC) to work with various stakeholders to identify and prioritize the future research that is most needed by decisionmakers. Given the clinical and economic importance of noninvasive testing for CAD in women, the ongoing investment in NIT research, and the remaining areas of uncertainty, we sought to create a prioritized research agenda that would represent the interests of diverse stakeholders and allow the remaining areas of uncertainty to be addressed. This report is a summary of that process and our findings.