# Table of Research Priorities Linked to Recent Publications and Ongoing Studies

Priority | Details
1 | What is the impact of NIT modalities on outcomes beyond diagnostic accuracy (risk stratification, prognostic information, treatment decisions, and clinical outcomes)? MEDLINE/EMBASE/Cochrane: Shaw LJ, Mieres JH, Hendel RH, et al. Comparative effectiveness of exercise electrocardiography with or without myocardial perfusion single photon emission computed tomography in women with suspected coronary artery disease: results from the What Is the Optimal Method for Ischemia Evaluation in Women (WOMEN) trial. Circulation 2011;124(11):1239–49. Shreibati JB, Baker LC, Hlatky MA. Association of coronary CT angiography or stress testing with subsequent utilization and spending among Medicare beneficiaries. JAMA 2011;306(19):2128–36. ClinicalTrials.gov: No relevant citations found
2 | Are women getting the same diagnostic testing as men? Are men over-tested and/or women under-tested? MEDLINE/EMBASE/Cochrane: No relevant citations found ClinicalTrials.gov: No relevant citations found
3 | What is the comparative accuracy in real world settings? (most of the studies were single center, best-quality/high expertise centers) MEDLINE/EMBASE/Cochrane: No relevant citations found ClinicalTrials.gov: No relevant citations found
4 | Does the comparative accuracy of NITs in women vary based on the pre-test probability of CAD of the women undergoing the test? How does the pre-test probability of CAD impact the findings on clinical decisionmaking? MEDLINE/EMBASE/Cochrane: No relevant citations found ClinicalTrials.gov: Comparison of Cardiac Imaging Techniques for Diagnosing Coronary Artery Disease, NCT01521468, Observational study of 210 patients.
5 | What is the comparative effect of NIT modalities on utilization, further testing, and impact on cost? MEDLINE/EMBASE/Cochrane: Shaw LJ, Mieres JH, Hendel RH, et al. Comparative effectiveness of exercise electrocardiography with or without myocardial perfusion single photon emission computed tomography in women with suspected coronary artery disease: results from the What Is the Optimal Method for Ischemia Evaluation in Women (WOMEN) trial. Circulation 2011;124(11):1239–49. Shreibati JB, Baker LC, Hlatky MA. Association of coronary CT angiography or stress testing with subsequent utilization and spending among Medicare beneficiaries. JAMA 2011;306(19):2128–36. ClinicalTrials.gov: Computed Tomography Versus Exercise Testing in Suspected Coronary Artery Disease, NCT01393028, RCT of 1350 patients. Role of Cardiac CT in Rapid Access Chest Pain Clinics (RADICAL), NCT01464203, RCT of 600 patients.
6 | Does the comparative accuracy of NITs in women vary based on patient risk profiles? MEDLINE/EMBASE/Cochrane: Becker MM, Zwicker C, Altiok E, et al. Accuracy of different stress modalities for evaluation of postmenopausal women with suspected coronary artery disease. European Heart Journal 2011;32 SUPPL. 1:164. Doyle M, Pohost GM, Shaw LJ, et al. Decisions informed by computing entities (DICE) to improve prognostic value of myocardial perfusion imaging: The NHLBI-sponsored women’s ischemia syndrome evaluation (WISE) study. Circulation 2011;124(21):2011–11. ClinicalTrials.gov: No relevant citations found Systematic reviews: Hlatky MA, Pryor DB, Harrell FE, Jr., et al. Factors affecting sensitivity and specificity of exercise electrocardiography. Multivariable analysis. Am J Med 1984;77(1):64–71.
7 | Is there a sequential order in which NITs should be used for evaluating CAD – i.e. multiple testing or layered-testing strategies? MEDLINE/EMBASE/Cochrane: No relevant citations found ClinicalTrials.gov: No relevant citations found
8 | What is the comparative safety and accuracy of functional versus anatomic NIT modalities? MEDLINE/EMBASE/Cochrane: No relevant citations found ClinicalTrials.gov: Comparison of Cardiac Imaging Techniques for Diagnosing Coronary Artery Disease, NCT01521468, Observational study of 210 patients. Stress Testing Compared to Coronary Computed Tomographic Angiography in Patients With Suspected Coronary Artery Disease, NCT01368770, RCT of 500 patients. Computed Tomography Versus Exercise Testing in Suspected Coronary Artery Disease, NCT01393028, RCT of 1350 patients.
9 | What is the comparative safety and accuracy of functional NIT testing strategies with and without imaging? MEDLINE/EMBASE/Cochrane: Shaw LJ, Mieres JH, Hendel RH, et al. Comparative effectiveness of exercise electrocardiography with or without myocardial perfusion single photon emission computed tomography in women with suspected coronary artery disease: results from the What Is the Optimal Method for Ischemia Evaluation in Women (WOMEN) trial. Circulation 2011;124(11):1239–49. Pubul V, Garrido M, Argibay S, et al. Gender differences and prognostic value in the exercise capacity and gated SPECT in patients with suspected coronary artery disease (CAD). European journal of nuclear medicine and molecular imaging 2011;38 SUPPL. 2:S311. ClinicalTrials.gov: Comparison of Low-radiation Dose CT Angiography With Invasive Coronary Angiography in Stable Coronary Disease, NCT01476579, Non-Randomized Interventional study of 800 patients. Systematic reviews: Kwok Y, Kim C, Grady D, et al. Meta-analysis of exercise testing to detect coronary artery disease in women. Am J Cardiol 1999;83(5):660–6.
10 | How would a better understanding of provider diagnostic ordering patterns and understanding of appropriate use guidelines to support evidence-based decision making impact the use of NITs? MEDLINE/EMBASE/Cochrane: No relevant citations found ClinicalTrials.gov: No relevant citations found
11 | Does the comparative accuracy of NITs in women vary based on differing symptomology and timing at presentation? MEDLINE/EMBASE/Cochrane: No relevant citations found ClinicalTrials.gov: No relevant citations found
12 | Does the comparative accuracy of NITs in women vary based on racial/ethnicity differences? MEDLINE/EMBASE/Cochrane: No relevant citations found ClinicalTrials.gov: No relevant citations found
13 | What is the value of performing a specific NIT test for the diagnosis of CAD in women, compared with no testing? MEDLINE/EMBASE/Cochrane: No relevant citations found ClinicalTrials.gov: No relevant citations found
14 | Does clinician preference, availability, or setting (outpatient versus chest pain unit of an emergency department) impact NIT use? MEDLINE/EMBASE/Cochrane: No relevant citations found ClinicalTrials.gov: No relevant citations found
15 | Does the comparative accuracy of NITs in women vary based on different settings (outpatient, inpatient, emergency room)? MEDLINE/EMBASE/Cochrane: No relevant citations found ClinicalTrials.gov: No relevant citations found
16 | Does the comparative accuracy of NITs in women vary based on: body size, heart size, menopausal status, functional status, stress modality? MEDLINE/EMBASE/Cochrane: Becker MM, Zwicker C, Altiok E, et al. Accuracy of different stress modalities for evaluation of postmenopausal women with suspected coronary artery disease. European Heart Journal 2011;32 SUPPL. 1:164. Siegler JC, Rehman S, Bhumireddy GP, et al. The accuracy of the electrocardiogram during exercise stress test based on heart size. PLoS One 2011;6(8):e23044. ClinicalTrials.gov: No relevant citations found
17 | How does patient preference of testing factor into decision making? MEDLINE/EMBASE/Cochrane: No relevant citations found ClinicalTrials.gov: No relevant citations found
18 | Does the comparative accuracy of NITs in women vary based on age? MEDLINE/EMBASE/Cochrane: No relevant citations found ClinicalTrials.gov: No relevant citations found
19 | What are the potential harms of NITs? MEDLINE/EMBASE/Cochrane: No relevant citations found ClinicalTrials.gov: Comparison of Low-radiation Dose CT Angiography With Invasive Coronary Angiography in Stable Coronary Disease, NCT01476579, Non-Randomized Interventional study of 800 patients.