# Exact Search Strings

The exact search strings used for this project are given below.

## Pubmed^®^ Search Strategy (Update of Search Performed for Original CER)

Search date: March 13, 2012

Number of articles: 159

((((/diagnosis OR diagnos* OR predict* OR predictive value of tests OR sensitivity OR specificity) OR (sensitiv*[Title/Abstract] OR sensitivity and specificity[MeSH Terms] OR diagnos*[Title/Abstract] OR diagnosis[MeSH:noexp] OR diagnostic *[MeSH:noexp] OR diagnosis, differential[MeSH:noexp] OR diagnosis[Subheading:noexp])) AND ((women OR woman OR female OR females OR sex factors) AND ((((CAD[tiab]) OR (coronary artery disease[mesh] OR “coronary artery disease”[tiab] OR coronary disease[mesh] OR “coronary disease”[tiab] OR “coronary heart disease”[tiab])) OR (Chest pain OR dyspnea OR shortness of breath OR angina)) AND (((echocardiography OR echo OR cardiogram) AND ((electrocardiography OR ECG OR EKG OR electrocardio* OR MCG OR multifunction cardiogram OR exercise test OR treadmill) OR (single photon emission computed tomography OR SPECT OR positron emission tomography OR “PET” OR myocardial perfusion imaging OR “nuclear scan” OR radionuclide imaging) OR (((cardio* OR heart OR coronary OR cardiac) AND “Tomography, X-Ray Computed”[Mesh]) OR (“CT angiography” OR CTA OR “Cardiac Computed Tomography” OR MSCT OR Multislice computed tomography OR Multi-slice computed tomography OR MDCT OR multidetector computed tomography OR multi-detector computed tomography OR “cardiac CT” OR “Cardiovascular CT”)) OR ((cardiac OR heart OR coronary OR cardio*) AND (magnetic resonance imaging OR MRI OR Magnetic resonance angiography OR MRA)) OR (cardiac catheterization OR angiography OR invasive coronary angiography OR heart catheterization OR coronary angiography OR “X-ray angiography” OR “Xray angiography”))) OR ((electrocardiography OR ECG OR EKG OR electrocardio* OR MCG OR multifunction cardiogram OR exercise test OR treadmill) AND ((echocardiography OR echo OR cardiogram) OR (single photon emission computed tomography OR SPECT OR positron emission tomography OR “PET” OR myocardial perfusion imaging OR “nuclear scan” OR radionuclide imaging) OR (((cardio* OR heart OR coronary OR cardiac) AND “Tomography, X-Ray Computed”[Mesh]) OR (“CT angiography” OR CTA OR “Cardiac Computed Tomography” OR MSCT OR Multislice computed tomography OR Multi-slice computed tomography OR MDCT OR multidetector computed tomography OR multi-detector computed tomography OR “cardiac CT” OR “Cardiovascular CT”)) OR ((cardiac OR heart OR coronary OR cardio*) AND (magnetic resonance imaging OR MRI OR Magnetic resonance angiography OR MRA)) OR (cardiac catheterization OR angiography OR invasive coronary angiography OR heart catheterization OR coronary angiography OR “X-ray angiography” OR “Xray angiography”))) OR ((single photon emission computed tomography OR SPECT OR positron emission tomography OR “PET” OR myocardial perfusion imaging OR “nuclear scan” OR radionuclide imaging) AND ((echocardiography OR echo OR cardiogram) OR (electrocardiography OR ECG OR EKG OR electrocardio* OR MCG OR multifunction cardiogram OR exercise test OR treadmill) OR (((cardio* OR heart OR coronary OR cardiac) AND “Tomography, X-Ray Computed”[Mesh]) OR (“CT angiography” OR CTA OR “Cardiac Computed Tomography” OR MSCT OR Multislice computed tomography OR Multi-slice computed tomography OR MDCT OR multidetector computed tomography OR multi-detector computed tomography OR “cardiac CT” OR “Cardiovascular CT”)) OR ((cardiac OR heart OR coronary OR cardio*) AND (magnetic resonance imaging OR MRI OR Magnetic resonance angiography OR MRA)) OR (cardiac catheterization OR angiography OR invasive coronary angiography OR heart catheterization OR coronary angiography OR “X-ray angiography” OR “Xray angiography”))) OR ((((cardio* OR heart OR coronary OR cardiac) AND “Tomography, X-Ray Computed”[Mesh]) OR (“CT angiography” OR CTA OR “Cardiac Computed Tomography” OR MSCT OR Multislice computed tomography OR Multi-slice computed tomography OR MDCT OR multidetector computed tomography OR multi-detector computed tomography OR “cardiac CT” OR “Cardiovascular CT”)) AND ((echocardiography OR echo OR cardiogram) OR (electrocardiography OR ECG OR EKG OR electrocardio* OR MCG OR multifunction cardiogram OR exercise test OR treadmill) OR (single photon emission computed tomography OR SPECT OR positron emission tomography OR “PET” OR myocardial perfusion imaging OR “nuclear scan” OR radionuclide imaging) OR ((cardiac OR heart OR coronary OR cardio*) AND (magnetic resonance imaging OR MRI OR Magnetic resonance angiography OR MRA)) OR (cardiac catheterization OR angiography OR invasive coronary angiography OR heart catheterization OR coronary angiography OR “X-ray angiography” OR “Xray angiography”))) OR (((cardiac OR heart OR coronary OR cardio*) AND (magnetic resonance imaging OR MRI OR Magnetic resonance angiography OR MRA)) AND ((echocardiography OR echo OR cardiogram) OR (electrocardiography OR ECG OR EKG OR electrocardio* OR MCG OR multifunction cardiogram OR exercise test OR treadmill) OR (single photon emission computed tomography OR SPECT OR positron emission tomography OR “PET” OR myocardial perfusion imaging OR “nuclear scan” OR radionuclide imaging) OR (((cardio* OR heart OR coronary OR cardiac) AND “Tomography, X-Ray Computed”[Mesh]) OR (“CT angiography” OR CTA OR “Cardiac Computed Tomography” OR MSCT OR Multislice computed tomography OR Multi-slice computed tomography OR MDCT OR multidetector computed tomography OR multi-detector computed tomography OR “cardiac CT” OR “Cardiovascular CT”)) OR (cardiac catheterization OR angiography OR invasive coronary angiography OR heart catheterization OR coronary angiography OR “X-ray angiography” OR “Xray angiography”))) OR ((cardiac catheterization OR angiography OR invasive coronary angiography OR heart catheterization OR coronary angiography OR “X-ray angiography” OR “Xray angiography”) AND ((echocardiography OR echo OR cardiogram) OR (electrocardiography OR ECG OR EKG OR electrocardio* OR MCG OR multifunction cardiogram OR exercise test OR treadmill) OR (single photon emission computed tomography OR SPECT OR positron emission tomography OR “PET” OR myocardial perfusion imaging OR “nuclear scan” OR radionuclide imaging) OR (((cardio* OR heart OR coronary OR cardiac) AND “Tomography, X-Ray Computed”[Mesh]) OR (“CT angiography” OR CTA OR “Cardiac Computed Tomography” OR MSCT OR Multislice computed tomography OR Multi-slice computed tomography OR MDCT OR multidetector computed tomography OR multi-detector computed tomography OR “cardiac CT” OR “Cardiovascular CT”)) OR ((cardiac OR heart OR coronary OR cardio*) AND (magnetic resonance imaging OR MRI OR Magnetic resonance angiography OR MRA)))))))) NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp])) NOT (Animals[Mesh:noexp])

Limits:

Publication Date: September 2011 – present

Language: English

## Pubmed^®^ Search Strategy (Search for Systematic Reviews)

Search date: March 26, 2012

Number of articles: 66

((((/diagnosis OR diagnos* OR predict* OR predictive value of tests OR sensitivity OR specificity) OR (sensitiv*[Title/Abstract] OR sensitivity and specificity[MeSH Terms] OR diagnos*[Title/Abstract] OR diagnosis[MeSH:noexp] OR diagnostic *[MeSH:noexp] OR diagnosis, differential[MeSH:noexp] OR diagnosis[Subheading:noexp])) AND ((women OR woman OR female OR females OR sex factors) AND ((((CAD[tiab]) OR (coronary artery disease[mesh] OR “coronary artery disease”[tiab] OR coronary disease[mesh] OR “coronary disease”[tiab] OR “coronary heart disease”[tiab])) OR (Chest pain OR dyspnea OR shortness of breath OR angina)) AND (((echocardiography OR echo OR cardiogram) AND ((electrocardiography OR ECG OR EKG OR electrocardio* OR MCG OR multifunction cardiogram OR exercise test OR treadmill) OR (single photon emission computed tomography OR SPECT OR positron emission tomography OR “PET” OR myocardial perfusion imaging OR “nuclear scan” OR radionuclide imaging) OR (((cardio* OR heart OR coronary OR cardiac) AND “Tomography, X-Ray Computed”[Mesh]) OR (“CT angiography” OR CTA OR “Cardiac Computed Tomography” OR MSCT OR Multislice computed tomography OR Multi-slice computed tomography OR MDCT OR multidetector computed tomography OR multi-detector computed tomography OR “cardiac CT” OR “Cardiovascular CT”)) OR ((cardiac OR heart OR coronary OR cardio*) AND (magnetic resonance imaging OR MRI OR Magnetic resonance angiography OR MRA)) OR (cardiac catheterization OR angiography OR invasive coronary angiography OR heart catheterization OR coronary angiography OR “X-ray angiography” OR “Xray angiography”))) OR ((electrocardiography OR ECG OR EKG OR electrocardio* OR MCG OR multifunction cardiogram OR exercise test OR treadmill) AND ((echocardiography OR echo OR cardiogram) OR (single photon emission computed tomography OR SPECT OR positron emission tomography OR “PET” OR myocardial perfusion imaging OR “nuclear scan” OR radionuclide imaging) OR (((cardio* OR heart OR coronary OR cardiac) AND “Tomography, X-Ray Computed”[Mesh]) OR (“CT angiography” OR CTA OR “Cardiac Computed Tomography” OR MSCT OR Multislice computed tomography OR Multi-slice computed tomography OR MDCT OR multidetector computed tomography OR multi-detector computed tomography OR “cardiac CT” OR “Cardiovascular CT”)) OR ((cardiac OR heart OR coronary OR cardio*) AND (magnetic resonance imaging OR MRI OR Magnetic resonance angiography OR MRA)) OR (cardiac catheterization OR angiography OR invasive coronary angiography OR heart catheterization OR coronary angiography OR “X-ray angiography” OR “Xray angiography”))) OR ((single photon emission computed tomography OR SPECT OR positron emission tomography OR “PET” OR myocardial perfusion imaging OR “nuclear scan” OR radionuclide imaging) AND ((echocardiography OR echo OR cardiogram) OR (electrocardiography OR ECG OR EKG OR electrocardio* OR MCG OR multifunction cardiogram OR exercise test OR treadmill) OR (((cardio* OR heart OR coronary OR cardiac) AND “Tomography, X-Ray Computed”[Mesh]) OR (“CT angiography” OR CTA OR “Cardiac Computed Tomography” OR MSCT OR Multislice computed tomography OR Multi-slice computed tomography OR MDCT OR multidetector computed tomography OR multi-detector computed tomography OR “cardiac CT” OR “Cardiovascular CT”)) OR ((cardiac OR heart OR coronary OR cardio*) AND (magnetic resonance imaging OR MRI OR Magnetic resonance angiography OR MRA)) OR (cardiac catheterization OR angiography OR invasive coronary angiography OR heart catheterization OR coronary angiography OR “X-ray angiography” OR “Xray angiography”))) OR ((((cardio* OR heart OR coronary OR cardiac) AND “Tomography, X-Ray Computed”[Mesh]) OR (“CT angiography” OR CTA OR “Cardiac Computed Tomography” OR MSCT OR Multislice computed tomography OR Multi-slice computed tomography OR MDCT OR multidetector computed tomography OR multi-detector computed tomography OR “cardiac CT” OR “Cardiovascular CT”)) AND ((echocardiography OR echo OR cardiogram) OR (electrocardiography OR ECG OR EKG OR electrocardio* OR MCG OR multifunction cardiogram OR exercise test OR treadmill) OR (single photon emission computed tomography OR SPECT OR positron emission tomography OR “PET” OR myocardial perfusion imaging OR “nuclear scan” OR radionuclide imaging) OR ((cardiac OR heart OR coronary OR cardio*) AND (magnetic resonance imaging OR MRI OR Magnetic resonance angiography OR MRA)) OR (cardiac catheterization OR angiography OR invasive coronary angiography OR heart catheterization OR coronary angiography OR “X-ray angiography” OR “Xray angiography”))) OR (((cardiac OR heart OR coronary OR cardio*) AND (magnetic resonance imaging OR MRI OR Magnetic resonance angiography OR MRA)) AND ((echocardiography OR echo OR cardiogram) OR (electrocardiography OR ECG OR EKG OR electrocardio* OR MCG OR multifunction cardiogram OR exercise test OR treadmill) OR (single photon emission computed tomography OR SPECT OR positron emission tomography OR “PET” OR myocardial perfusion imaging OR “nuclear scan” OR radionuclide imaging) OR (((cardio* OR heart OR coronary OR cardiac) AND “Tomography, X-Ray Computed”[Mesh]) OR (“CT angiography” OR CTA OR “Cardiac Computed Tomography” OR MSCT OR Multislice computed tomography OR Multi-slice computed tomography OR MDCT OR multidetector computed tomography OR multi-detector computed tomography OR “cardiac CT” OR “Cardiovascular CT”)) OR (cardiac catheterization OR angiography OR invasive coronary angiography OR heart catheterization OR coronary angiography OR “X-ray angiography” OR “Xray angiography”))) OR ((cardiac catheterization OR angiography OR invasive coronary angiography OR heart catheterization OR coronary angiography OR “X-ray angiography” OR “Xray angiography”) AND ((echocardiography OR echo OR cardiogram) OR (electrocardiography OR ECG OR EKG OR electrocardio* OR MCG OR multifunction cardiogram OR exercise test OR treadmill) OR (single photon emission computed tomography OR SPECT OR positron emission tomography OR “PET” OR myocardial perfusion imaging OR “nuclear scan” OR radionuclide imaging) OR (((cardio* OR heart OR coronary OR cardiac) AND “Tomography, X-Ray Computed”[Mesh]) OR (“CT angiography” OR CTA OR “Cardiac Computed Tomography” OR MSCT OR Multislice computed tomography OR Multi-slice computed tomography OR MDCT OR multidetector computed tomography OR multi-detector computed tomography OR “cardiac CT” OR “Cardiovascular CT”)) OR ((cardiac OR heart OR coronary OR cardio*) AND (magnetic resonance imaging OR MRI OR Magnetic resonance angiography OR MRA)))))))) NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp])) NOT (Animals[Mesh:noexp])

Limits:

Reviews and Meta-analyses

Publication Date: September 2011 – present

Language: English

## Embase^®^ Search Strategy (Update of Search Performed for Original CER)

Search date: March 13, 2012

Number of articles: 145

‘echocardiography’/exp OR echo OR echocardiogram AND (‘electrocardiography’/exp OR ‘electrocardiogram’/exp OR electrocardiography OR ecg OR ekg OR electrocardio* OR mcg OR ‘multifunction cardiogram’ OR (‘cardiopulmonary exercise test’/exp AND ‘exercise test’/exp OR exercise AND test) OR treadmill) OR (‘echocardiography’/exp OR echo OR echocardiogram AND (‘single photon emission computer tomography’/exp OR ‘computer assisted emission tomography’/exp OR ‘myocardial perfusion imaging’/exp OR ‘single photon emission computed tomography’ OR spect OR ‘positron emission tomography’ OR pet OR ‘myocardial perfusion imaging’ OR ‘nuclear scan’ OR ‘radionuclide imaging’ OR ‘heart scintiscanning’/exp)) OR (‘echocardiography’/exp OR echo OR echocardiogram AND (cardio* OR heart OR coronary OR cardiac) AND (‘computer assisted tomography’/exp OR ‘computed tomographic angiography’/exp OR ‘multidetector computed tomography’/exp OR ‘ct angiography’ OR cta OR ‘cardiac computed tomography’ OR ‘msct’ OR ‘multislice computed tomography’ OR ‘multi-slice computed tomography’ OR mdct OR ‘multidetector computed tomography’ OR ‘multi-detector computed tomography’ OR ‘cardiac ct’ OR ‘cardiovascular ct’)) OR (‘echocardiography’/exp OR echo OR echocardiogram AND (cardio* OR heart OR coronary OR cardiac) AND (‘nuclear magnetic resonance imaging’/exp OR ‘magnetic resonance angiography’/exp OR ‘magnetic resonance imaging’ OR mri OR ‘magnetic resonance angiography’ OR mra)) OR (‘electrocardiography’/exp OR ‘electrocardiogram’/exp OR electrocardiography OR ecg OR ekg OR electrocardio* OR mcg OR ‘multifunction cardiogram’ OR (‘cardiopulmonary exercise test’/exp AND ‘exercise test’/exp OR exercise AND test) OR treadmill AND (‘single photon emission computer tomography’/exp OR ‘computer assisted emission tomography’/exp OR ‘myocardial perfusion imaging’/exp OR ‘single photon emission computed tomography’ OR spect OR ‘positron emission tomography’ OR pet OR ‘myocardial perfusion imaging’ OR ‘nuclear scan’ OR ‘radionuclide imaging’ OR ‘heart scintiscanning’/exp)) OR (‘electrocardiography’/exp OR ‘electrocardiogram’/exp OR electrocardiography OR ecg OR ekg OR electrocardio* OR mcg OR ‘multifunction cardiogram’ OR (‘cardiopulmonary exercise test’/exp AND ‘exercise test’/exp OR exercise AND test) OR treadmill AND (cardio* OR heart OR coronary OR cardiac) AND (‘computer assisted tomography’/exp OR ‘computed tomographic angiography’/exp OR ‘multidetector computed tomography’/exp OR ‘ct angiography’ OR cta OR ‘cardiac computed tomography’ OR ‘msct’ OR ‘multislice computed tomography’ OR ‘multi-slice computed tomography’ OR mdct OR ‘multidetector computed tomography’ OR ‘multi-detector computed tomography’ OR ‘cardiac ct’ OR ‘cardiovascular ct’)) OR (‘electrocardiography’/exp OR ‘electrocardiogram’/exp OR electrocardiography OR ecg OR ekg OR electrocardio* OR mcg OR ‘multifunction cardiogram’ OR (‘cardiopulmonary exercise test’/exp AND ‘exercise test’/exp OR exercise AND test) OR treadmill AND (cardio* OR heart OR coronary OR cardiac) AND (‘nuclear magnetic resonance imaging’/exp OR ‘magnetic resonance angiography’/exp OR ‘magnetic resonance imaging’ OR mri OR ‘magnetic resonance angiography’ OR mra)) OR (‘single photon emission computer tomography’/exp OR ‘computer assisted emission tomography’/exp OR ‘myocardial perfusion imaging’/exp OR ‘single photon emission computed tomography’ OR spect OR ‘positron emission tomography’ OR pet OR ‘myocardial perfusion imaging’ OR ‘nuclear scan’ OR ‘radionuclide imaging’ OR ‘heart scintiscanning’/exp AND (cardio* OR heart OR coronary OR cardiac) AND (‘computer assisted tomography’/exp OR ‘computed tomographic angiography’/exp OR ‘multidetector computed tomography’/exp OR ‘ct angiography’ OR cta OR ‘cardiac computed tomography’ OR ‘msct’ OR ‘multislice computed tomography’ OR ‘multi-slice computed tomography’ OR mdct OR ‘multidetector computed tomography’ OR ‘multi-detector computed tomography’ OR ‘cardiac ct’ OR ‘cardiovascular ct’)) OR (‘computer assisted tomography’/exp OR ‘computed tomographic angiography’/exp OR ‘multidetector computed tomography’/exp OR ‘ct angiography’ OR cta OR ‘cardiac computed tomography’ OR ‘msct’ OR ‘multislice computed tomography’ OR ‘multi-slice computed tomography’ OR mdct OR ‘multidetector computed tomography’ OR ‘multi-detector computed tomography’ OR ‘cardiac ct’ OR ‘cardiovascular ct’ AND (cardio* OR heart OR coronary OR cardiac) AND (‘nuclear magnetic resonance imaging’/exp OR ‘magnetic resonance angiography’/exp OR ‘magnetic resonance imaging’ OR mri OR ‘magnetic resonance angiography’ OR mra)) OR (‘single photon emission computer tomography’/exp OR ‘computer assisted emission tomography’/exp OR ‘myocardial perfusion imaging’/exp OR ‘single photon emission computed tomography’ OR spect OR ‘positron emission tomography’ OR pet OR ‘myocardial perfusion imaging’ OR ‘nuclear scan’ OR ‘radionuclide imaging’ OR ‘heart scintiscanning’/exp AND (cardio* OR heart OR coronary OR cardiac) AND (‘nuclear magnetic resonance imaging’/exp OR ‘magnetic resonance angiography’/exp OR ‘magnetic resonance imaging’ OR mri OR ‘magnetic resonance angiography’ OR mra)) OR (cardio* OR heart OR coronary OR cardiac AND (‘nuclear magnetic resonance imaging’/exp OR ‘magnetic resonance angiography’/exp OR ‘magnetic resonance imaging’ OR mri OR ‘magnetic resonance angiography’ OR mra) AND (‘heart catheterization’/exp OR ‘cardiac catheterization’ OR angiography OR ‘invasive coronary angiography’ OR ‘heart catheterization’ OR ‘coronary angiography’ OR ‘x-ray angiography’ OR ‘xray angiography’)) OR (‘heart catheterization’/exp OR ‘cardiac catheterization’ OR angiography OR ‘invasive coronary angiography’ OR ‘heart catheterization’ OR ‘coronary angiography’ OR ‘x-ray angiography’ OR ‘xray angiography’ AND (‘echocardiography’/exp OR echo OR echocardiogram)) OR (‘heart catheterization’/exp OR ‘cardiac catheterization’ OR angiography OR ‘invasive coronary angiography’ OR ‘heart catheterization’ OR ‘coronary angiography’ OR ‘x-ray angiography’ OR ‘xray angiography’ AND (‘electrocardiography’/exp OR ‘electrocardiogram’/exp OR electrocardiography OR ecg OR ekg OR electrocardio* OR mcg OR ‘multifunction cardiogram’ OR (‘cardiopulmonary exercise test’/exp AND ‘exercise test’/exp OR exercise AND test) OR treadmill)) OR (‘single photon emission computer tomography’/exp OR ‘computer assisted emission tomography’/exp OR ‘myocardial perfusion imaging’/exp OR ‘single photon emission computed tomography’ OR spect OR ‘positron emission tomography’ OR pet OR ‘myocardial perfusion imaging’ OR ‘nuclear scan’ OR ‘radionuclide imaging’ OR ‘heart scintiscanning’/exp AND (‘heart catheterization’/exp OR ‘cardiac catheterization’ OR angiography OR ‘invasive coronary angiography’ OR ‘heart catheterization’ OR ‘coronary angiography’ OR ‘x-ray angiography’ OR ‘xray angiography’)) OR (cardio* OR heart OR coronary OR cardiac AND (‘computer assisted tomography’/exp OR ‘computed tomographic angiography’/exp OR ‘multidetector computed tomography’/exp OR ‘ct angiography’ OR cta OR ‘cardiac computed tomography’ OR ‘msct’ OR ‘multislice computed tomography’ OR ‘multi-slice computed tomography’ OR mdct OR ‘multidetector computed tomography’ OR ‘multi-detector computed tomography’ OR ‘cardiac ct’ OR ‘cardiovascular ct’) AND (‘heart catheterization’/exp OR ‘cardiac catheterization’ OR angiography OR ‘invasive coronary angiography’ OR ‘heart catheterization’ OR ‘coronary angiography’ OR ‘x-ray angiography’ OR ‘xray angiography’)) AND (‘thorax pain’/exp OR ‘dyspnea’/exp OR ‘angina pectoris’/exp OR ‘chest pain’ OR ‘shortness of breath’ OR angina OR dsypnea OR ‘coronary artery disease’/exp OR ‘ischemic heart disease’/exp OR cad OR ‘coronary artery disease’ OR ‘coronary disease’ OR ‘coronary heart disease’) AND (‘female’/exp OR female OR women OR woman OR females OR ‘sex difference’/exp) AND (predict OR specificity OR diagnosis:lnk) AND [embase]/lim NOT [medline]/lim AND [humans]/lim AND [english]/lim AND [2000–2011]/py NOT (‘case report’/exp OR ‘editorial’/exp OR ‘letter’/exp OR ‘note’/exp)

Limits:

Publication Date: September 2011 – present

## Cochrane Search Strategy (Update of Search Performed for Original CER)

Search date: March 13, 2012

Number of articles: 167

[Cochrane Central Registry of Controlled Trials and Cochrane Database of Systematic Reviews]

Chest pain OR dyspnea OR shortness of breath OR angina OR CAD OR coronary artery disease OR coronary disease OR coronary heart disease

AND

((echocardiography OR echo OR cardiogram) AND ((electrocardiography OR ECG OR EKG OR electrocardio* OR MCG OR multifunction cardiogram OR exercise test OR treadmill) OR (single photon emission computed tomography OR SPECT OR positron emission tomography OR PET OR myocardial perfusion imaging OR nuclear scan OR radionuclide imaging) OR (((cardio* OR heart OR coronary OR cardiac) AND X-Ray computed Tomography) OR (CT angiography OR CTA OR Cardiac Computed Tomography OR MSCT OR Multislice computed tomography OR Multi-slice computed tomography OR MDCT OR multidetector computed tomography OR multi-detector computed tomography OR cardiac CT OR Cardiovascular CT)) OR ((cardiac OR heart OR coronary OR cardio*) AND (magnetic resonance imaging OR MRI OR Magnetic resonance angiography OR MRA)) OR (cardiac catheterization OR angiography OR invasive coronary angiography OR heart catheterization OR coronary angiography OR X-ray angiography OR Xray angiography))) OR ((electrocardiography OR ECG OR EKG OR electrocardio* OR MCG OR multifunction cardiogram OR exercise test OR treadmill) AND ((echocardiography OR echo OR cardiogram) OR (single photon emission computed tomography OR SPECT OR positron emission tomography OR PET OR myocardial perfusion imaging OR nuclear scan OR radionuclide imaging) OR (((cardio* OR heart OR coronary OR cardiac) AND X-Ray computed Tomography) OR (CT angiography OR CTA OR Cardiac Computed Tomography OR MSCT OR Multislice computed tomography OR Multi-slice computed tomography OR MDCT OR multidetector computed tomography OR multi-detector computed tomography OR cardiac CT OR Cardiovascular CT)) OR ((cardiac OR heart OR coronary OR cardio*) AND (magnetic resonance imaging OR MRI OR Magnetic resonance angiography OR MRA)) OR (cardiac catheterization OR angiography OR invasive coronary angiography OR heart catheterization OR coronary angiography OR X-ray angiography OR Xray angiography))) OR ((single photon emission computed tomography OR SPECT OR positron emission tomography OR PET OR myocardial perfusion imaging OR nuclear scan OR radionuclide imaging) AND ((echocardiography OR echo OR cardiogram) OR (electrocardiography OR ECG OR EKG OR electrocardio* OR MCG OR multifunction cardiogram OR exercise test OR treadmill) OR (((cardio* OR heart OR coronary OR cardiac) AND X-Ray computed Tomography) OR (CT angiography OR CTA OR Cardiac Computed Tomography OR MSCT OR Multislice computed tomography OR Multi-slice computed tomography OR MDCT OR multidetector computed tomography OR multi-detector computed tomography OR cardiac CT OR Cardiovascular CT)) OR ((cardiac OR heart OR coronary OR cardio*) AND (magnetic resonance imaging OR MRI OR Magnetic resonance angiography OR MRA)) OR (cardiac catheterization OR angiography OR invasive coronary angiography OR heart catheterization OR coronary angiography OR X-ray angiography OR Xray angiography))) OR ((((cardio* OR heart OR coronary OR cardiac) AND X-Ray computed Tomography) OR (CT angiography OR CTA OR Cardiac Computed Tomography OR MSCT OR Multislice computed tomography OR Multi-slice computed tomography OR MDCT OR multidetector computed tomography OR multi-detector computed tomography OR cardiac CT OR Cardiovascular CT)) AND ((echocardiography OR echo OR cardiogram) OR (electrocardiography OR ECG OR EKG OR electrocardio* OR MCG OR multifunction cardiogram OR exercise test OR treadmill) OR (single photon emission computed tomography OR SPECT OR positron emission tomography OR PET OR myocardial perfusion imaging OR nuclear scan OR radionuclide imaging) OR ((cardiac OR heart OR coronary OR cardio*) AND (magnetic resonance imaging OR MRI OR Magnetic resonance angiography OR MRA)) OR (cardiac catheterization OR angiography OR invasive coronary angiography OR heart catheterization OR coronary angiography OR X-ray angiography OR Xray angiography))) OR (((cardiac OR heart OR coronary OR cardio*) AND (magnetic resonance imaging OR MRI OR Magnetic resonance angiography OR MRA)) AND ((echocardiography OR echo OR cardiogram) OR (electrocardiography OR ECG OR EKG OR electrocardio* OR MCG OR multifunction cardiogram OR exercise test OR treadmill) OR (single photon emission computed tomography OR SPECT OR positron emission tomography OR PET OR myocardial perfusion imaging OR nuclear scan OR radionuclide imaging) OR (((cardio* OR heart OR coronary OR cardiac) AND X-Ray computed Tomography) OR (CT angiography OR CTA OR Cardiac Computed Tomography OR MSCT OR Multislice computed tomography OR Multi-slice computed tomography OR MDCT OR multidetector computed tomography OR multi-detector computed tomography OR cardiac CT OR Cardiovascular CT)) OR (cardiac catheterization OR angiography OR invasive coronary angiography OR heart catheterization OR coronary angiography OR X-ray angiography OR Xray angiography))) OR ((cardiac catheterization OR angiography OR invasive coronary angiography OR heart catheterization OR coronary angiography OR X-ray angiography OR Xray angiography) AND ((echocardiography OR echo OR cardiogram) OR (electrocardiography OR ECG OR EKG OR electrocardio* OR MCG OR multifunction cardiogram OR exercise test OR treadmill) OR (single photon emission computed tomography OR SPECT OR positron emission tomography OR PET OR myocardial perfusion imaging OR nuclear scan OR radionuclide imaging) OR (((cardio* OR heart OR coronary OR cardiac) AND X-Ray computed Tomography) OR (CT angiography OR CTA OR Cardiac Computed Tomography OR MSCT OR Multislice computed tomography OR Multi-slice computed tomography OR MDCT OR multidetector computed tomography OR multi-detector computed tomography OR cardiac CT OR Cardiovascular CT)) OR ((cardiac OR heart OR coronary OR cardio*) AND (magnetic resonance imaging OR MRI OR Magnetic resonance angiography OR MRA))))

AND

women OR woman OR female OR females OR sex factors

AND

diagnosis OR diagnos* OR predict* OR predictive value of tests OR sensitivity OR specificity OR sensitive OR diagnostic OR differential diagnosis

Limits:

Publication Date: September 2011 – present

## Clinicaltrials.gov (Update of Search Performed for Original CER)

Search date: March 13, 2012

Number of trials: 21

noninvasive [ALL-FIELDS] AND coronary artery disease [DISEASE] AND ( NOT “Male” ) [GENDER] AND “completed” [SUMMARY-STATUS]

Limits:

Publication Date: September 2011 – present