# Abbreviations

AHA: American Heart Association
AHRQ: Agency for Healthcare Research and Quality
CAD: Coronary artery disease
CER: Comparative Effectiveness Review
CMR: Cardiac magnetic resonance
CTA: Computed tomography angiograph
ECG: Electrocardiography
ECHO: Echocardiography
EPC: Evidence-based Practice Center
KQ: Key Question
NIT: Noninvasive technology
PET: Positron emission tomography
PICO: Population, interventions, comparators, and outcomes
RCT: Randomized controlled trial
SPECT: Single-photon emission computed tomography