# Results

## Research Needs

Appendix E provides a synthesis of research needs from the CER, those proposed by panel members during the individual introductory calls, and results of the literature search update. The Stakeholder Panel was asked to review this preliminary list of research needs during the first teleconference call. These needs were grouped based on the PICOTS framework used in the CER. The panel members discussed the implications of the published studies and ongoing trials identified through the literature search update during the first call. Issues brought forth for discussion at this call included:

- Who may benefit from MRSA screening? One key issue is to identify the appropriate populations for screening as this has implications for decision making about universal screening or ‘one size fits all’ legislative approaches.
- What are the most effective tests for MRSA screening? MRSA screening cannot be considered as a sole intervention; this needs to be coupled with other interventions to determine the impact of a MRSA screening strategy. The efficacy of interventions such as decolonization and contact isolation has not been assessed adequately in current research initiatives (e.g., How do those interventions compare to other infection control strategies with respect to reducing MRSA infection?).
- What outcomes should be considered in evaluation of MRSA screening?
  ○ From an emergency department (ED) perspective, we should expand our concept of adverse events to consider the broader impact on patient flow system-wide, recognizing that some of the adverse outcomes may occur in patients who are not part of the screening program.
  ○ Since payers are now partnering with hospitals regarding patient quality and safety issues, areas of key concern are whom to screen, how to screen, and which outcomes to measure (e.g., the downstream effects of treatment, including antimicrobial resistance and complications). There are actuarial implications for high-quality health care based on these outcomes, and it would be desirable to be partners and support these efforts.
- From a microbiological perspective, a ‘one size fits all’ approach may not work because of the wide variation in types of blood isolates and disparity between nasal and blood isolates across the U.S..11 Without knowing the origin of the various organisms, prevention of MRSA transmission through nasal colonization eradication will be difficult to achieve.

A total of seven research needs were identified through a combination of the CER findings and conversations with the Stakeholder Panel. The results of the first survey ranking the importance of these research needs are found in Appendix F. The response rate was 100 percent (n=10); all seven research needs received votes. The final seven research needs are stated in Table 2 (in order of priority).

Table 2 Prioritized list of research needs

1. What are the central components of a MRSA screening strategy?; 2. Who may benefit from MRSA screening?^*^; 3. What outcomes should be considered for evaluations of MRSA screening?^*^; 4. What are the most effective tests for MRSA screening?; 5. What factors could influence MRSA test results (e.g., when to screen, which sites to swab)?; 6. What are the appropriate comparators for MRSA screening?; 7. From which perspective(s) should evaluations of MRSA screening be conducted (e.g., societal, hospital, emergency room, patient, payer)?

MRSA = methicillin-resistant Staphylococcus aureus

* Both questions received equal votes.

The Stakeholder Panel provided feedback during the second teleconference call on the survey results in terms of their importance to clinical and patient decision making. The panel members concurred that the overall rankings highlight the major issues. Panel members highlighted the difficultly in prioritizing these research needs given their inter-relatedness; for example, the top-ranked research need on the central components of an MRSA screening strategy encompasses many of the other research needs on this list (e.g., research needs 2, 3, and 4). Panel members discussed the need to address the fundamentals of screening (e.g., who is at high risk, who may benefit, what are the key components of a screening strategy, and how this might differ depending on which risk groups are under study, etc.). Further issues brought forth for discussion at the second call included:

- From a consumer perspective, the most negative impact is acquiring MRSA infection in the health-care setting. Every new patient infected with MRSA represents a need for prevention in the U.S. health care system and for patient-outcomes research (i.e., this produces a gap in consumer confidence and trust in our health care system). Screening needs to be best viewed as a tool for prevention of spread and active infections within a health care setting.
  ○ Methodologic transparency is important to consumers. Choice of outcomes will depend on what is most valid and important to report and generalizable across all health care settings with clear description of how they are measured. There is a need to ensure that these outcomes are fair measures for hospitals so that consumers can make informed decisions about their care.
- From a public health perspective, early detection and intervention are secondary prevention strategies which may only work in certain patient populations or certain high risk situations. It is important that future studies not lose sight of primary prevention of disease and the injury associated with it.
- Evaluation of MRSA screening.
  ○ The effectiveness of a particular strategy will depend on the followup action of a positive screen, and the goals of the strategy (e.g., whether to prevent transmission or undergo treatment). There are many potential followup actions and variables to consider that will require multiple study questions.
  ○ When evaluating various strategies, there is a need to consider the benefits and harms to the individuals exposed to the strategy (e.g., screened), as well as to other patients who were not directly exposed to the strategy.
  ○ Screening should be assessed in an environment that employs best practices routinely for prevention of MRSA infections, e.g., evaluating an ICU population in an environment where all ventilator-associated pneumonia preventive practices are already in place. The challenge in studying this issue in terms of health outcomes such as newly documented MRSA infections or attributable mortality is the low rate of MRSA infection in specific health-care settings.
- While there are several ongoing clinical trials, additional research is needed to determine the role of screening-guided decolonization therapy versus universally applied decolonization therapy in applied more universally in certain high risk patient populations (e.g., role of the universal application of contact precaution gown and gloving in ICU or surgical patients).

## Research Questions

Following the second Stakeholder Panel call, the EPC drafted a preliminary list of research questions to address the prioritized research needs and solicited feedback from panel members via email. This feedback was incorporated into a second survey of research questions that was submitted to Panel members for ranking prior to the third Stakeholder Panel call. As with the research needs, the research questions were presented in a random order for the survey. The results of the second survey ranking the importance of the research questions are found in Appendix G. The response rate was 100 percent (n=10); 16 (of 19) questions received votes.

The panel members discussed consolidating some of the research questions into a short list to take forward. The panel members concurred that the two top-ranked questions relating to surgical admissions and for the intensive care setting highlighted the major issues. As with the research needs, panel members discussed the difficulty in prioritizing the research questions given their inter-relatedness. The Stakeholder Panel also discussed the importance and usefulness of future studies on the top-ranked questions based on the voting results at the third panel call.

Future research issues brought forth for discussion on the third call were:

- General issues:
  ○ It was proposed that the research questions address both adult and pediatric populations (rather than treating the latter as a separate study group). Rather than formulating specific research questions for pediatrics, it would be beneficial to integrate this segment of the population within the two patient groups prioritized in the research needs (i.e., surgical patients, ICU patients), recognizing that future studies in children will need a separate analysis. An important subgroup to address within the pediatric population would be the neonates within the intensive care setting.
  ○ The fundamental question of whether screening works will depend on the patient population of interest as MRSA rates may differ by patient group. A study could look at MRSA screening versus non-screening strategies for identifying high risk patient populations targeted for interventions.
  ○ Many patients come into the hospital not colonized with MRSA and leave colonized. The number of patients who become colonized likely exceeds the number of patients who become infected. Since more than 80 percent of infected patients are infected with their own colonizing strain, a strategy that prevents colonization would be desirable. Therefore, colonization acquisition should be assessed as a part of any study. This would mean measuring colonization upon hospital admission, during hospitalization and at discharge in the study population.
- Specific issues:
  ○ Question rank 1: For surgical admissions, what is the most effective strategy for reducing HA-MRSA infection, morbidity, mortality and resource use? It would be important to determine whether to address all surgical patients or the listed subgroups of patients who are most likely to benefit? For example, there is a need to identify a priori who is actually considered “high risk” (e.g., general surgery patients vs. orthopedic or cardiac surgery patients) as these patient groups may have different risk profiles for MRSA.
  ○ Question rank 2: In the intensive care setting, what is the most effective strategy for reducing MRSA infection rates, morbidity, mortality and resource use for patients with a positive MRSA culture? The phrase “patients with a positive MRSA culture” (which is interpreted as a positive MRSA screening culture implying that screening is an implicit part of the strategy) should be deleted to allow comparison of screening versus non-screening based strategies. For example, one could compare a screening based strategy that identifies, isolates, and decolonizes carriers + standard measures with a non-screening based strategy that applies only standard measures to all patients (which needs to be defined but may include a hand hygiene program, chlorhexidine bathing, adherence to central line-associated bloodstream infection and ventilator-associated pneumonia bundle measures, etc.). This comment also applies to question rank 7 related to general medical adult inpatients.
  ○ Question rank 5: What factors are associated with increased risk of HA-MRSA infection among general medical adult inpatients? This choice focuses on what could be considered basic research needs – i.e., who are the high-risk groups (within selected categories of patients) who may actually benefit from screening if it were performed (or other targeted infection prevention strategies) and does screening work (in comparison to non-screening/broader-based infection prevention strategies) to prevent infections. Preventing transmission is important, but as an endpoint it may not be useful if we cannot show that preventing transmission equates preventing actual infection.
  ○ Question rank 10: What factors are associated with increased risk of MRSA infection in surgical inpatients? This question should not be limited to surgical inpatients, as many surgeries involving implants (prosthetic joints) in patients who may be at increased risk for HA-MRSA infection are performed electively, and surgical patients often come from the outpatient setting. One of the logistical issues is how best to screen surgical outpatients prior to surgery (if a screening-based strategy is used).
  ○ Question rank 15: What is the most effective strategy for preventing MRSA infection among carriers after discharge from the hospital? This question is important from a public health perspective based on population-based surveillance data of invasive MRSA disease that includes both community-onset and health care-acquired infections. Most cases of community-onset invasive disease occur outside of the hospital setting but involve patients who have been exposed to MRSA in hospitals. At present, there are lack of data about how to prevent infections in this population; there are few studies to date looking at decolonizing patients when they leave the hospital.

These discussions formed the basis for the final prioritized list of seven research questions (Table 3; in order of the key prioritized populations).

Table 3 Prioritized list of research questions

1. For surgical admissions, what is the most effective strategy for reducing MRSA acquisition and infection rates and improving morbidity, mortality, patient flow and resource use?; 2. For surgical admissions what factors are associated with increased risk of MRSA acquisition and infection?; 3. For intensive care populations, what is the most effective strategy for reducing MRSA acquisition and infection rates and improving morbidity, mortality, patient flow and resource use?; 4. For the neonatal intensive care setting, what is the most effective strategy for reducing MRSA acquisition and infection rates and improving morbidity, mortality, patient flow and resource use?; 5. For intensive care populations, what factors are associated with increased risk of HA-MRSA acquisition and infection?; 6. For general medical inpatients, what is the most effective strategy for reducing MRSA acquisition and infection rates and associated morbidity, mortality, patient flow and resource use?; 7. For general medical inpatients, what factors are associated with increased risk of HA-MRSA acquisition and infection?

HA = hospital acquired; MRSA = methicillin-resistant Staphylococcus aureus

## Study Design Considerations

The Stakeholder Panel discussed specific aspects of study designs and potential designs for the prioritized list of research questions at the third panel call. Issues brought forth for discussion at this call included:

- Comparators: It is important to design a trial that includes non-screening test based strategies. For example, hand hygiene would be a highly relevant comparator. If there was 100 percent compliance among health care workers for hand hygiene, some of the need for contact precautions to prevent transmission may not be required. This is a fundamental element of infection prevention, and it has not really been studied in any well-designed manner. One challenge in comparing culture decolonization with a nonculture-based strategy like gowning and gloving would be how to conduct a randomized study in one institution; a multicenter study may be the best option.
- Outcomes: It is important to clarify the study objectives as they will determine the appropriate outcomes for the study. For example, in the surgical population, the more appropriate outcome may be preventing surgical site infection whereas for the ICU population, MRSA acquisition would be of more concern.
- Timing: It is important to consider the time point at which the screening is being done and the time point at which the interventions are undertaken based on the screening results. Likewise, the effect of screening results on the time interval from ED admission to hospital admission, would have implications for the effectiveness of screening as well as for some of the associated effects of screening such as patient flow (e.g., from ambulatory care/ED into the high-risk setting) and negative secondary outcomes on patient populations who were not screened. For example, one study design might introduce screening on alternate days at a hospital ED that currently does not do screening; those who screen positive for MRSA would be admitted into contact isolation. A comparison of the median time interval between ED admission and hospital admission on screening versus non-screening days would assess the potential negative impact of screening on downstream patient flow.
  When should you screen elective surgical admissions? Should you screen patients when they have their pre-surgical evaluation at the time of admission? Logistical issues would need to be addressed such as communication of test results that may require, for example, a team approach to coordinate results and follow up with appropriate interventions (e.g., decolonization prior to surgery). If screening is performed in the inpatient setting, is there enough time to receive a timely result and act upon this before the patient goes to the operating room?
- Study designs: In terms of robust designs, the cluster randomized clinical trial (RCT) offers the opportunity to compare different MRSA strategies. From an epidemiological perspective, there is a need to discuss the pros and cons of cluster trials, e.g., challenges of doing them and the desired outcomes, because different studies will have different objectives and outcomes.12 Although more cluster RCTs will emerge within the next year and a half, realistically the cost of these trials will prevent many from being done. It may be harder to address rare outcomes such as infection rates using cluster RCTs because very large studies would be needed, so other study designs need to be considered.

For the assessment of study designs, EPC staff evaluated the appropriateness of various designs for each prioritized research question. For the three questions that identify factors associated with an increased risk of MRSA acquisition and infection in these priority populations, epidemiological studies offer the most valid and practical approaches to quantify the relationship between risk factors and disease. They are: cohort studies; nested case-control or case-control studies; and cross-sectional studies. On the other hand, for the four remaining questions that address the effectiveness of MRSA screening, experimental designs are needed to determine the causal effect of MRSA screening strategies on patient outcomes. The optimal design would allow the researcher to address multiple research needs by manipulating one or more variables and controlling and measuring their effects on other variables, while balancing the feasibility and practicality of carrying out the design. The EPC staff proposed the following study designs: cluster randomized controlled trials; quasi-experimental (before-after) studies; and modeling.

Higher quality before-and-after or quasi experimental studies at multiple sites that account for secular trends may be able to address Key Questions. These include identifying patients at high-risk for MRSA acquisition or infection, determining the actual turn-around times for various screening tests such as multiplex PCR analysis and blood tests, and determining which anatomical sites to screen. If the design of these types of studies is improved, they may be a less-costly option compared with the cluster randomized trial.

The project team identified additional study-design considerations:

- Who would benefit from screening? There are unanswered questions regarding the value of universal screening versus targeted screening strategies. From a practical standpoint, targeted screening may be more feasible to undertake at this time. Knowledge about risk factors can be used to identify high risk populations suitable as target groups for MRSA prevention strategies. Risk factors for HA-MRSA acquisition include recent hospitalization, having an invasive device or residing in a long term care facility. Risk factors for community-acquired MRSA identified in outbreak reports include participation in contact sports and living in crowded or unsanitary conditions. However, some populations (e.g., pediatrics) in which MRSA colonization is quite prevalent may present with none of the known risk factors making targeted screening difficult to undertake and universal screening impractical to implement.
- Alternate study designs for consideration
  ○ Cross-sectional studies may identify the prevalence of other factors that place these populations at risk. Patients with these risk factors, especially mutable risk factors, may then be targeted for prevention/intervention strategies. Definitions of a number of patient characteristics and outcomes would need to be formulated a priori. This design would not be suitable for rare outcomes such as MRSA infection rates.
  ○ Cohort studies and case-control studies may be used to compare the incidence of MRSA acquisition or infection between the intervention (screening) and control groups. Case-control studies may be more feasible or practical when the occurrence of new cases is relatively rare (e.g., HA-MRSA infection). Interventional studies could possibly combine questions of treatment effectiveness with evaluation of less-studied hypothesized risk factors (e.g., livestock exposure or living in urban underserved populations in community-acquired MRSA) as well as known risk factors (e.g., exposure to a health care setting).
  ○ In these studies it is essential to choose a representative sampling of the source population with justification for sample size to minimize selection bias. The internal validity should be ensured through methodologic transparency that accounts for such design elements as data completeness (e.g., loss to followup, missing data) and variables that may bias the results. The external validity of results may allow for generalization of the results to other settings and for comparison of health care institutions that would permit providers and other stakeholders (e.g., patients, payers) to make informed decisions regarding the quality of care.

Tables 4 and 5 present the final prioritized lists of research questions along with feedback from the Stakeholder Panelists that were incorporated into the PICOTS information. Similar PICOTS elements (e.g., interventions and outcomes) can be applied to questions 2, 5 and 7 that identify factors that increase the risk of MRSA acquisition and infection across the three priority patient groups (i.e., surgery, intensive care, general medical inpatients) in Table 4. Likewise, similar PICOTS elements (e.g. interventions, comparators and primary outcomes) can be applied to questions 1, 3, 4 and 6 that address the effectiveness of MRSA screening in these priority patient groups, as shown in Table 5.

Table 4 Prioritized list of risk factor research questions with PICOTS information

Research Question | Population(s) | Interventions | Comparators | Outcomes | Timing | Settings
For surgical admissions what factors are associated with increased risk of MRSA acquisition and infection? | Full or representative sample of surgical admissions:; - Ambulatory care/ED admissions; - Surgical unit admissions; - Elective admissions | - MRSA screening/culture; - Surveillance of potential risk factors for MRSA acquisition or infection (e.g., interview, questionnaire, database) | - No screening; - Surveillance of potential risk factors for MRSA acquisition or infection (e.g., interview, questionnaire, database) | - MRSA surgical site infection rate; - MRSA acquisition rates; - Risk factors for MRSA acquisition; - Risk factors for MRSA infection | - On admission e.g., in the ED or surgical unit; - Pre-admission; - At discharge; - At followup visit | - Inpatient; - Outpatient; - Non-outbreak setting ·
For intensive care populations, what factors are associated with increased risk of HA-MRSA acquisition and infection? | Full or representative sample of intensive care admissions with the potential to acquire MRSA. May come from:; - Ambulatory care/ED; - General inpatient population | - MRSA screening/culture; - Surveillance of potential risk factors for MRSA acquisition or infection (e.g., interview, questionnaire, database) | - No screening; - Surveillance of potential risk factors for MRSA acquisition or infection (e.g., interview, questionnaire, database) | - MRSA acquisition; - Risk factors for MRSA acquisition; - MRSA infection; - Risk factors for MRSA infection | - On admission e.g., in the ED or ICU | - Inpatient; - Non-outbreak setting
For general medical inpatients, what factors are associated with increased risk of HA-MRSA acquisition and infection? | Full or representative sample of general medical admissions with the potential to acquire MRSA. May come from:; - Ambulatory care/ED; - Elective admissions | - MRSA screening/culture; - Surveillance of potential risk factors for MRSA acquisition or infection (e.g., interview, questionnaire, database) | - No screening; - Surveillance of potential risk factors for MRSA acquisition or infection (e.g., interview, questionnaire, database) | - MRSA acquisition; - Risk factors for MRSA acquisition; - MRSA infection; - Risk factors for MRSA infection | - On admission e.g., in the ED or to the ward | - Outpatient (for elective admissions); - Inpatient; - Non-outbreak setting

ED = emergency department; HA = hospital acquired; ICU = intensive care unit; MRSA = methicillin-resistant Staphylococcus aureus; PICOTS = population(s), interventions, comparators, outcomes, timing, settings

Table 5 Prioritized list of effectiveness research questions with PICOTS information

Research Question | Population(s) | Interventions | Comparators | Outcomes | Timing | Settings
1. For surgical admissions, what is the most effective strategy for reducing MRSA acquisition and infection rates and improving morbidity, mortality, patient flow and resource use? | - Broad range of risk categories (low, medium, high) for universal screening strategies or; - High risk populations for targeted screening strategies | - Screening-based strategy (e.g., screening and decolonization) + standard care precautions; Types of MRSA screening tests to be considered:; - Multiplex PCR; - Culture; Site(s) of MRSA screening:; - Nares, throat, axilla, groin, perirectal; - Optimal number of sites to swab; - Optimal anatomical sites; - Separate swabs for each site vs. one swab for all sites | - Non-screening test based strategy (e.g., gowning and gloving, hand hygiene, or standard care precautions) | - MRSA surgical site infection rate; - Staff compliance with infection control procedures; - Patient flow (e.g., median time interval between ED arrival and hospital admission); - Morbidity (e.g., complications of MRSA infection); - MRSA-attributable mortality; - Harms (e.g., allergic reaction to treatment, satisfaction of patients in isolation); - Resource use (e.g., length of stay); - Turn-around times for test results; - Cost-benefit analysis | - Time point at which screening is done e.g., admission in ambulatory care or surgical unit; - Time point at which intervention is initiated based on screening results; - Time point at ED arrival; - Time point at hospital admission | - Inpatient (e.g., ambulatory care/ED, surgical unit); - Outpatient; - Non-outbreak setting
3. For intensive care populations, what is the most effective strategy for reducing MRSA acquisition and infection rates and improving morbidity, mortality, patient flow and resource use? 4. For the neonatal intensive care setting, what is the most effective strategy for reducing MRSA acquisition and infection rates and improving morbidity, mortality, patient flow and resource use? | - Broad range of risk categories (low, medium, high) for universal screening strategies or; - High risk populations for targeted screening strategies | - Screening-based strategy (e.g., screening and decolonization) + standard care precautions; Types of MRSA screening tests to be considered:; - Multiplex PCR; - Culture; Site(s) of MRSA screening:; - Nares, throat, axilla, groin; - Optimal number of sites to swab; - Optimal anatomical sites; - Separate swabs for each site vs. one swab for all sites | - Non-screening test based strategy (e.g., gowning and gloving, hand hygiene, or standard care precautions only) | - MRSA acquisition rate; - MRSA infection rate; - Staff compliance with infection control procedures; - Patient flow (e.g., median time interval between ED arrival and hospital admission); - Morbidity (e.g., complications of MRSA infection); - MRSA-attributable mortality; - Harms (e.g., allergic reaction to treatment, satisfaction of patients in isolation); - Resource use (e.g., length of stay); - Turn-around times for test results; - Mother-to-child transmission rate (for neonates only); - Cost-benefit analysis | - Time point at which screening is done e.g., admission in ambulatory care or surgical unit; - Time point at which intervention is initiated based on screening results; - Time point at ED arrival; - Time point at hospital admission | - Inpatient (e.g., ambulatory care/ED, ICU, labor and delivery); - Non-outbreak setting
6. For general medical inpatients, what is the most effective strategy for reducing MRSA acquisition and infection rates and associated morbidity, mortality, patient flow and resource use? | - Broad range of risk categories (low, medium, high) for universal screening strategies or; - High risk populations for targeted screening strategies | - Screening-based strategy (e.g., screening and decolonization) + standard care precautions; Types of MRSA screening tests to be considered:; - Multiplex PCR; - Culture; Site(s) of MRSA screening:; - Nares, throat, axilla, groin; - Optimal number of sites to swab; - Optimal anatomical sites; - Separate swabs for each site vs. one swab for all sites | - Non-screening based strategy (e.g., gowning and gloving, hand hygiene, or standard care precautions only) | - MRSA acquisition rate; - MRSA infection rate; - Staff compliance with infection control procedures; - Patient flow (e.g., median time interval between ED arrival and hospital admission); - Morbidity (e.g., complications of MRSA infection); - MRSA-attributable mortality; - Harms (e.g., allergic reaction to treatment, satisfaction of patients in isolation); - Resource use (e.g., length of stay); - Turn-around times for test results; - Cost-benefit analysis | - Time point at which screening is done (e.g., admission in ambulatory care or on ward); - Time point at which intervention is initiated based on screening results; - Time point at ED arrival; - Time point at hospital admission | - Inpatient (e.g., ambulatory care/ED, ward); - Outpatient for elective admissions; - Non-outbreak setting

ED = emergency room; ICU = intensive care unit; MRSA = methicillin-resistant Staphylococcus aureus; PCR = polymerase chain reaction; PICOTS = population(s), interventions, comparators, outcomes, timing, settings

The EPC considered the Stakeholder Panelists’ feedback when recommending the most valid and feasible study designs for future research of MRSA screening that may be considered for each of the prioritized research questions. Table 6 presents study designs for identifying factors associated with an increased risk of MRSA acquisition and infection in three priority populations (surgical, intensive care and general medical), which, in turn, may help target strategies toward those who are most likely to benefit from MRSA prevention strategies. Table 7 displays the most feasible and valid experimental study designs for determining the effectiveness of interventions for preventing and treating MRSA acquisition and infection in four priority populations (surgical, intensive care, neonatal intensive care, general medical).

Table 6 Study design considerations for determining associations between risk factors and outcomes

Research Question 2. For surgical admissions what factors are associated with increased risk of MRSA acquisition and infection?

Research Question 5. For intensive care populations, what factors are associated with increased risk of HA-MRSA acquisition and infection?

Research Question 7. For general medical inpatients, what factors are associated with increased risk of HA-MRSA acquisition and infection?

Study Design Considerations | Cohort Study | Nested Case-Control Study | Case-Control Study | Cross-Sectional Study
Description of design | Individuals nonrandomly assigned MRSA prevention strategy or other strategy by physician and followed for a defined period. Data gathered on effectiveness and risk factors of interest. May be done prospectively or retrospectively. | A sampling of patients who have been exposed to MRSA prevention strategy and developed infection (cases) or did not develop infection (controls) are included from a prospective cohort and followed for a defined period. Data on risk factors are collected retrospectively. May be nested within prospective studies of treatment effectiveness. | Patients with MRSA acquisition or infection are compared with patients without MRSA, with a retrospective review of how many patients in each group were exposed to the MRSA prevention strategy and other risk factors. | Both the exposure and outcome status of a target population are assessed concurrently to estimate prevalence of possible risk factors in need of further study.
Advantages of study design for producing a valid result | Prospective cohort studies permit calculation of relative risk and measure events in temporal sequence thereby distinguishing causes from effects. Baseline characteristics may not be balanced and susceptible to confounders, but results may be more generalizable. Susceptible to bias such as selection bias and loss to follow up. Disadvantages include reliance on existing data that may have been collected for another purpose or may have key data missing. | Usually more valid than case-control study but balance of baseline characteristics is largely dependent on the original cohort. Disadvantages of this design include reliance on existing data which may be incomplete, confounders and bias such as sampling bias. | Relatively quick to collect data, but has multiple threats to validity. Sample should accurately reflect population of interest and sampling method should be clearly described. Useful for generating hypotheses that can be tested in experimental designs. Large numbers of exposure variables can be studied, but only one outcome variable can be studied at a time. May be the only option for collecting information on rare outcomes such as HA-MRSA infection. Permits estimation of relative risk through an odds ratio. | Fairly quick and inexpensive to conduct. Can study multiple outcomes. Design is not suitable for the study of rare outcomes. Susceptible to recall bias. Does not differentiate between cause and effect or the sequence of events. Study can generate a hypothesis regarding causation which can be tested in prospective cohort or randomized clinical trial designs.
Resource use, size and duration | Likely to require substantial resources to collect epidemiological data of interest and to recruit adequate sample sizes, and multiple sites may be needed. Duration of followup will depend on desired outcome. Retrospective cohorts where available are cheaper and quicker but are susceptible to incomplete data collection that was collected for a different purpose, as well as to multiple threats to validity such as sampling bias and confounders such as staff compliance with infection control procedures. | Resources are low as it uses existing data and fewer subjects. Duration may be shorter than prospective studies. | Comparatively few subjects are required so more resources may be available for studying each subject. Requires collecting data on exposure to MRSA prevention strategy, which may or may not be easy to collect (e.g., if transferred from another hospital). Duration of study is relatively brief. | Only one group is used, data are collected only once and multiple outcomes can be studied; thus this type of study is relatively inexpensive. Resources may be higher than a nested case-control study as more subjects may be needed depending on the study question and outcome of interest.
Ethical, legal, and social issues | Fewer ethical issues than with RCT because of non-randomized assignment. Enrollment and consent of critically ill or urgent care patients could be an issue. | Minimal since data are already collected and no intervention is involved. | Generally low since events (exposures and outcomes) have already occurred. | Generally low since no intervention is involved, but could be moderate if additional data collection is needed.
Availability of data or ability to recruit | This design is generally more acceptable to participants. Recruitment may be slow at any one site, and multiple centers may be needed. | Availability of data should be high, since study sample data already collected. | Generally high since events have already occurred but collecting data on exposures can be difficult if multiple sites are involved. | This design is generally acceptable to participants. Some data may be already available.

HA = hospital acquired; MRSA = methicillin-resistant Staphylococcus aureus; RCT = randomized controlled trial

Table 7 Study design considerations for determining the effectiveness of strategies for prevention and treatment of MRSA acquisition and infection in target populations

Research Question 1. For surgical admissions, what is the most effective strategy for reducing MRSA acquisition and infection rates and improving morbidity, mortality, patient flow and resource use?

Research Question 3. For intensive care populations, what is the most effective strategy for reducing MRSA acquisition and infection rates and improving morbidity, mortality, patient flow and resource use?

Research Question 4. For the neonatal intensive care setting, what is the most effective strategy for reducing MRSA acquisition and infection rates and improving morbidity, mortality, patient flow and resource use?

Research Question 6. For general medical inpatients, what is the most effective strategy for reducing MRSA acquisition and infection rates and associated morbidity, mortality, patient flow and resource use?

Study Design Considerations | Randomized Controlled Trial | Quasi-Experimental: Before-After study (Variations) | Modeling
Description of design | Individuals or groups randomly assigned to receive one of two or more strategies for prevention or treatment, depending on the goal of the study. Outcomes include incidence of MRSA infection, MRSA acquisition and other outcomes such as MRSA carriage. Other associated cases (e.g., staff, roommates of study subjects) may be followed similarly. Longer followup post implementation may be required if sustainability of outcome is desired. Cluster RCTs that randomize at a hospital or ward level are more suitable for population-level strategies when outcomes for individuals from a given unit are not independent. If pooling data across institutions is required, consensus on outcome measures, minimum datasets and followup periods would be needed. | Incidence of MRSA compared in a group of individuals before and after exposure to the preventive strategy or treatment strategy. Investigator controls timing of measurement(s) and variables (e.g., baseline disease severity) measured, but not all intervention variables are in the control of the investigator. Data on potential confounding factors and temporal trends would be needed. If pooling data across institutions is required, consensus on outcome measures, minimum datasets and followup periods would be needed. | Simulation model developed and validated to assess the value of individual strategies or individual components of bundled strategies across a range of populations, settings and conditions. Use of agent based modeling for tracking MRSA transmission and infection would allow for assessing the impact of different interventions.
Advantages of study design for producing a valid result | Although individual RCTs are generally the preferred research design, in this context cluster RCTs are preferred because of the likelihood of interdependence of care patterns, background infection rates, and outcomes within a given hospital or unit. It should produce the most valid results, but the use of clusters often limits the available sample size. Requires planning to balance baseline characteristics and sample size considerations to achieve adequate power. | Simple design with generalizable results. May be best option if randomization is not possible. Highly susceptible to confounding variables, regression to the mean and maturation effects. Internal validity may be strengthened by use of a concurrent non-randomized comparison group that is not exposed to the preventive strategy or exposed to a different strategy, by multiple pre-intervention observations and by replication in different groups at multiple times. These studies must have adequate statistical methods to control for confounding and secular trends, otherwise no causal inference can be made. | May be the best option to use when questions cannot be addressed using conventional clinical trial methods or existing data analysis. May inform and help focus future clinical trials and data collection. Models can be tailored to multiple end users/perspectives, conditions and settings to enhance generalizability of findings and to help target interventions (different situations may call for different interventions). Other forms of modeling (e.g., compartment based, decision tree, etc.) can be informative but will require more assumptions and thus greater variability with less confidence in the results.
Resource use, size and duration | Depending on the strategy and desired effect size, costs, sample size and staff time needed for recruitment and implementation could be high. Recruitment of individuals or unit “clusters” willing to be randomized may be a constraint on sample size. Duration of hospitalization is likely to be brief which may keep costs down, but if sustainability of outcome or delayed outcomes such as MRSA acquisition or infection rates is desired, then longer followup may be required. | Generally less resource intensive than an experimental design. Otherwise, size and duration issues would be similar to RCT. | May require substantial personnel time but is generally less resource intensive than primary studies. Once agent based modeling identifies the transmission chains of MRSA, other modeling studies (e.g., decision tree) can be performed, but may require primary data collection to inform components if reliable estimates cannot be obtained from the literature, empiric studies or experts.
Ethical, legal, and social issues | For cluster RCTs, a waiver of informed consent may be required. Legal mandates or clinical culture may impede randomization to novel interventions or supersede trial objectives. | Need for informed consent, unless the comparison is done retrospectively. Legal mandates or clinical culture may supersede trial objectives. | Additional data collection may require institutional approvals or informed consent.
Availability of data or ability to recruit | Cluster RCTs require collaborative network of sites willing to participate. Strategies implemented at the unit level require participation of all individuals within that unit, which could affect recruitment. | Recruitment is generally feasible, particularly where randomization is unacceptable. Strategies implemented at the unit level require participation of all individuals within that unit, which could affect recruitment. | Data would be obtained primarily from published sources, proprietary institutional databases, and expert opinion.

MRSA = methicillin-resistant Staphylococcus aureus; RCT = randomized controlled trial