# References

1 Glick SB, Webber S, Huang E, et al. Screening for Methicillin-Resistant Staphylococcus aureus (MRSA). Comparative Effectiveness Review No. 102. (Prepared by Blue Cross and Blue Shield Association Technology Evaluation Center Evidence-based Practice Center under Contract No. 290-2007-10058-I.) AHRQ Publication No. 13-EHC143-EF. Rockville, MD. Agency for Healthcare Research and Quality. Forthcoming 2013. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
2 Barton E, MacGowan A. Future treatment options for Gram-positive infections--looking ahead. Clin Microbiol Infect. Suppl 6. 2009;15:17-25. [pmid: 19917023].
3 Burton DC, Edwards JR, Horan TC, et al. Methicillin-resistant Staphylococcus aureus central line-associated bloodstream infections in US intensive care units, 1997–2007. JAMA. 2009;301:727-36. [pmid: 19224749].
4 Herold BC, Immergluck LC, Maranan MC, et al. Community-acquired methicillin-resistant Staphylococcus aureus in children with no identified predisposing risk. JAMA. 1998;279:593-8. [pmid: 9486753].
5 Kallen AJ, Mu Y, Bulens S, et al. Health care-associated invasive MRSA infections, 2005–2008. JAMA. 2010;304:641-8. [pmid: 20699455].
6 Klevens RM, Morrison MA, Nadle J, et al. Invasive Methicillin-Resistant Staphylococcus aureus Infections in the United States. JAMA. 2007;298:63-1771. [pmid: 17940231].
7 Maree CL, Daum RS, Boyle-Vavra S, et al. Community-associated methicillin-resistant Staphylococcus aureus isolates causing healthcare-associated infection. Emerg Infect Sis. 2007;13:236-42. [pmid: 17479885].
8 Whitlock EP, Lopez SA, Chang S, et al. AHRQ Series Paper 3: Identifying, selecting, and refining topics for comparative effectiveness systematic reviews: AHRQ and the Effective Health Care Program. J Clin Epidemiol. 2010;63:491-501. [pmid: 19540721].
9 Carey T, Sanders GD, Viswanathan M, et al. Framework for Considering Study Designs for Future Research Needs. Methods Future Research Needs Paper No. 8. (Prepared by the RTI–UNC Evidence-based Practice Center under Contract No. 290-2007-10056-I.) AHRQ Publication No. 12-EHC048-EF. Rockville, MD. Agency for Healthcare Research and Quality. March. 2012. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
10 Robinson KA, Saldanha IJ, Mckoy NA. Frameworks for determining research gaps during systematic reviews. Methods Future Research Needs Report No. 2. (Prepared by the Johns Hopkins University Evidence-based Practice Center under Contract No. HHSA 290-2007-10061-I.) AHRQ Publication No. 11-EHC043-EF. Rockville, MD. Agency for Healthcare Research and Quality. June. 2011. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
11 Tenover FC, Tickler IA, Goering RV, et al. for the MRSA Consortium. Characterization of Nasal and Blood Culture Isolates of Methicillin-Resistant Staphylococcus aureus from Patients in United States Hospitals. Antimicrob Agents Chemother. 2012;56:1324-30. [pmid: 22155818].
12 Perencevich EN, Lautenbach E. Infection prevention and comparative effectiveness research. JAMA. 2011;305:1482-3. [pmid: 21486981].