# Methods

## Identification of Research Needs

Figure 3 outlines the process steps of this Future Research Needs project. The details are described in the text. First, the evidence gaps (i.e., research needs) identified in the BCBCS TEC EPC CER found insufficient evidence to recommend or refute the need for universal, targeted or expanded screening. The CER identified several evidence gaps (i.e., research needs) that needed to be addressed in future comparative effectiveness research. A Stakeholder Panel was convened to help prioritize these gaps and associated questions. The Evidence-based Practice Center (EPC) updated the literature search from the CER and searched clinicaltrials.gov to identify any recently completed or ongoing research studies that might address the research needs. Through an iterative process the Stakeholder Panel refined and prioritized the research needs and then generated and prioritized a list of research questions to address in future research (see section on engagement of stakeholders, researchers and funders). Research needs were prioritized using the SurveyMonkey^®^ Web site. Finally, the EPC explored various research designs to address the research needs.

Figure 3 Process flow diagram

AHRQ = Agency for Healthcare Research and Quality; CER = Comparative Effectiveness Review; EHC = Effective Health Care; EPC = Evidence-based Practice Center

Figure 3 outlines the 11-step process steps of this future research needs project. First, evidence gaps were identified through the BCBSA TEC EPC CER. The literature search was updated and clinicaltrials.gov was searched to identify any ongoing research studies that might address the evidence gaps. Next, stakeholders were identified and through and iterative process the gaps were shared with and refined by these stakeholders. A group of nine stakeholders (Stakeholder Panel (SP)) representing diverse perspectives was formed; this group prioritized the research needs, and generated research questions. Research needs were prioritized through the Web using the SurveyMonkey® Web site. Finally, the exploration of various research designs was conducted by the EPC. The details are described in the text.

## Literature Search Update

Rather than carry out a full update of the CER, we sought to identify recent, ongoing studies potentially addressing research needs and research question identification. We conducted searches on PubMed^®^, Embase ^®^, The Cochrane Library^®^, and the Clinicaltrials.gov database. The update captured 57 citations containing studies published since March 1, 2012, including 19 studies from Embase, 26 NCT clinical trials underway, recruiting, or with results, and 11 PubMed^®^ studies. The Cochrane Library^®^ yielded one new controlled trial report. Given the short time parameter (3 months), subject searches for MRSA and variations for MRSA were done using a MeSH^®^ and free text studies filter (see Appendix B).

## Criteria for Prioritization

To establish criteria for prioritization, we modified the Effective Health Care (EHC) Program Selection Criteria to be applicable to primary research rather than to systematic reviews of original research.8 The Panel used the modified selection criteria to prioritize both research needs and corresponding research questions. The EPC staff compiled a final list, taking the Panel members’ comments into consideration and paying particular attention to areas where ongoing efforts might overlap with prioritized research questions. Prioritization of study designs was handled by the EPC in accordance with the recent Future Research Needs methods report by the EPCs on behalf of the Agency for Healthcare Research and Quality (AHRQ).9 The Stakeholder Panel provided insight into how future research agendas and proposed studies to address research needs fit within these prespecified criteria (see Table 1).

Table 1 Prioritization criteria for research needs and proposed research studies

Category | Criterion
Current importance | - Incorporates both clinical benefits and harms; - Represents important variation in clinical care due to controversy/uncertainty regarding appropriate care; - Addresses high costs to consumers, patients, health-care systems, or payers; - Utility of available evidence limited by changes in practice, for example disease detection
Potential for significant health impact | - Potential for significant health impact:; ○ To improve [underlined: health outcomes]; ○ To reduce [underlined: significant variation] related to quality of care; ○ To reduce [underlined: unnecessary burden] on those with health-care problems; - Potential for significant economic impact, reducing unnecessary or excessive costs.; - Potential for evidence-based change.; - Potential risk from inaction, for example lack of evidence for decision-making produces unintended harms; - Addresses inequities, vulnerable populations, patient subgroups with differential impact (e.g., by age)
Incremental value | - Adds useful new information to existing portfolio of research on topic OR; - Validates existing research when body of evidence is scant.
Feasibility | Factors to be considered:; - Interest among researchers; - Duration; - Cost; - Methodological complexity (e.g., do existing methods need to be refined?); - Implementation difficulty; - Facilitating factors; - Potential funders

### Methods for Ranking Research Needs

Research needs were ranked via the SurveyMonkey^®^ Web site. The Stakeholder Panel was sent a link to the Web site where they ranked the research needs from 1 to 5 and generated research questions for each research need. The survey allowed each rank to be used only once. Points were assigned to each research need: 1 point for a ranking of fifth, up to 5 points for a ranking of first. The research need with the largest number of points was assigned the highest priority. The research needs were presented in a random order for the survey.

The comments received from the Stakeholder Panel were reviewed by EPC staff and incorporated where necessary. In addition to the modified EHC Program Selection Criteria, special attention was paid to where research needs overlapped with existing research. The reasons for each research need were categorized based on a classification scheme created by the Johns Hopkins University EPC on behalf of AHRQ.10

### Engagement of Stakeholders, Researchers, Funders

Central to the methodology of this report was the use of the Stakeholder Panel to identify and prioritize research needs. A single multidisciplinary Stakeholder Panel was convened to provide input on this project. The Panel consisted of 10 participants representing diverse clinical perspectives (from infectious diseases, critical care, pediatrics, emergency medicine), methodological expertise (e.g., guidelines development, clinical trials, epidemiology), and consumer and payer representation. Panel members brought forth specific clinical and research experience on MRSA screening, infection control, antimicrobial resistance, and new diagnostic/treatment strategies.

The Stakeholder Panel was asked to recommend important studies published since the BCBSA TEC EPC completed the CER,1 revise and prioritize the research needs listed in the CER and gathered throughout this project, and develop and prioritize a list of potential research questions to address those research needs. As required by AHRQ, conflict of interest forms were completed by all panel members and staff on this project. The multidisciplinary character of the Stakeholder Panel and their varied affiliations enriched the process.

The Stakeholder Panel was asked to participate in three conference calls (1 hour each) over the project duration, and some interim communications by email. In addition, a brief introductory call (30 minutes) was scheduled separately with each individual member, to provide an overview of the project, to discuss the role of the Stakeholder Panel, and to solicit preliminary suggestions on further research needs. The first call was held on May 25, 2012. During this call, the members were asked to review the preliminary list of research needs. This list was a synthesis of research needs from the CER, those proposed by panel members during the individual introductory calls, and results of the literature search update. Members reviewed a list of revised research needs following this call. The Stakeholder Panel was then asked to rank, via an online survey, their top five research needs from 1 to 5 with 1 having the highest priority and 5 the lowest. Panel members rated these research needs based on revised EHC program selection criteria (Appendix C).

The second call was scheduled on June 6, 2012. During the second call, Stakeholder Panel members were invited to review the prioritized list of research needs and “brainstorm” research questions to address each research need. Members reviewed a list of potential research questions following this call. The Stakeholder Panel was then asked to prioritize the research questions via an online survey instrument (using SurveyMonkey™) similar to that used for selection of research needs. As with the online survey for research needs, members were asked to rank their top five research questions from 1 to 5 with 1 having the highest priority and 5 the lowest (Appendix D). The project team collated the “votes” and reported the results at the third call, convened on June 22, 2012, for prioritization of research questions. The meeting participants reviewed the results and discussed the importance of the research questions to patient and clinical decision making. These discussions formed the basis for the final prioritized list of research questions submitted to AHRQ. All teleconference call materials were distributed a few days prior to scheduled calls. To enhance public engagement, AHRQ will solicit broader input on this document from the public, which will be incorporated and reflected in the final report.

### Research Question Development and Study Design Considerations

Key Questions for each research need were generated through an online survey instrument and discussions with the Stakeholder Panel (discussed previously). The project team compiled a final list of research questions taking the feedback of the Panel into consideration. The research needs and research questions were characterized using the PICOTS framework consisting of the population(s) (P), interventions (I), comparators (C), outcomes (O), timing (T), and settings (S).11 The project team evaluated potential study designs to address each of the key research questions consistent with the guidance published by RTI-UNC EPC commission by AHRQ.10 The appropriateness of a study design to address a research need was further evaluated using the following criteria:

- Advantages of the study design for producing a valid result
- Resource use, size, and duration
- Ethical, legal, and social issues
- Availability of data or ability to recruit

The project team relied on this framework10 as a guide during discussions of the least biased study design that was most feasible to undertake. Public comments received after the document is posted will be incorporated into the final report.