# Introduction

## Background

### MRSA Incidence

Methicillin-resistant Staphylococcus aureus (MRSA) emerged as a clinically relevant human pathogen more than five decades ago.1 The virulent bacterium was first detected in hospitals and other health care facilities where vulnerable hosts, frequent exposure to the selective pressure of intensive antimicrobial therapy, and the necessity for invasive procedures created a favorable environment for dissemination. MRSA emerged as an important cause of health care–acquired infections, particularly central line-associated bloodstream infection, ventilator-associated pneumonia, and surgical site infection. Despite the adoption of infection control measures, the incidence of MRSA infection at most hospitals in the United States (U.S.) steadily increased for many years, but is now decreasing.2–5

In 2005, population-based surveillance in the U.S. found the standardized incidence rate of invasive MRSA was 31.8 per 100,000 (interval estimate 24.4–35.2); the standardized mortality rate was 6.3 per 100,000 (interval estimate, 3.3–7.5).6 Eighty-five percent of the invasive MRSA infections were health-care acquired and 13.7 percent community acquired; the etiology of 1.3 percent of the infections could not be determined.6 Estimates based on these data suggest that 94,360 invasive MRSA infections occurred in the U.S. in 2005 and that 18,650 of these infections were fatal.6

### Screening Strategies

Conventional strategies for the control of MRSA (whether hospital- or community-acquired) have focused on the prevention of spread from patient to patient (horizontal transmission). While hand hygiene remains the cornerstone of MRSA transmission-control efforts and use of contact isolation has been widely promoted and adopted, these strategies have failed to adequately control MRSA. Routine clinical cultures may miss a large portion of patients who are silent carriers of these organisms and serve as reservoirs for further transmission. MRSA screening is receiving greater attention for its potential value in identifying carriers of MRSA to prevent further transmission.

To identify the population of colonized individuals, microbiological samples are obtained from at-risk patients even in the absence of signs or symptoms of infection. The screening strategy may use a testing modality with a rapid turnaround time (results available on the same day as the testing is performed, typically using polymerase chain reaction [PCR]), intermediate turnaround time (results available next day to 2 days after testing performed) or longer turnaround time (results available greater than 2 days after testing performed, typically culture). Because screening alone is not expected to affect health outcomes, screening strategies may include screening with or without isolation and with or without attempted decolonization or eradication.

By detecting the larger population of colonized individuals, at the very least conventional precautions (i.e., hand hygiene and contact isolation) can be implemented in a broader and timelier manner to interrupt horizontal transmission of MRSA. Detection of colonized patients also permits consideration of more aggressive interventions, including attempts at microbiological eradication or decolonization.

### Objectives and Rationale of Comparative Effectiveness Review

The objective of the Comparative Effectiveness Review (CER), Screening for Methicillin-Resistant Staphylococcus aureus (MRSA), prepared by the Blue Cross and Blue Shield Association Technology Evaluation Center Evidence-based Practice Center (BCBSA TEC EPC) was to synthesize comparative studies that examined the benefits or harms of screening for MRSA carriage in the inpatient or outpatient settings.1 The review examined MRSA-screening strategies applied to all hospitalized or ambulatory patients (universal screening), as well as screening strategies applied to selected inpatient or outpatient populations (e.g., patients admitted to the intensive care unit (ICU), patients admitted for a surgical procedure, or patients at high-risk of MRSA colonization or infection such as those on prolonged antibiotic therapy) and compared them to no screening or to screening of selected patient populations (targeted screening). The review evaluated MRSA-screening strategies that included screening with or without isolation and with or without attempted eradication/decolonization. The review included all ambulatory patients (outpatients) and hospitalized patients (inpatients).

Because conventional strategies have failed to adequately control MRSA, more aggressive measures have been promoted in an effort to check the spread of this particularly virulent pathogen. In some European countries, an aggressive containment program called “search and destroy” identifies contacts of colonized and infected patients in an effort to intercede to prevent dissemination. While such aggressive measures have not been widely adopted in most settings, some clinicians, scientists, and increasing numbers of public advocates and legislators have raised the call for more intensive efforts at MRSA control in the United States (U.S.) Particular attention has been given to the potential value of active surveillance screening for MRSA. Routine clinical cultures may identify as few as 18 percent of patients with asymptomatic carriage of antibiotic- resistant organisms such as MRSA leaving a large reservoir of patients who are silent carriers of these organisms. These individuals may serve as a reservoir for further transmission.

However, a limitation of these approaches—and specifically the use of isolation precautions— are their potential negative consequences. A series of studies have associated isolation precautions with worsened outcomes in terms of safety and patient satisfaction. Isolation precautions may be associated with worsened patient safety and satisfaction. In addition, questions have been raised about the effect of isolation precautions on specific performance measures such as the frequency with which patients on isolation precautions are visited by treating physicians and the timely recording of vital signs, but no rigorous definitive analysis has been completed to exonerate isolation precautions.

Therefore, while the specific evidence in support of active surveillance for MRSA has been promising, a number of questions remain about its effectiveness and whether screening should be applied to all patient populations (universal screening) or to selected populations (targeted screening). Thus, a systematic review of the evidence is both justified and timely. The importance of gaining a better understanding of the evidence is also highlighted by the increasing demand for better control of MRSA and a higher standard for prevention of hospital-acquired (HA) infections in general.

The following four Key Questions formed the basis for the CER:

Key Question 1 Among ambulatory or hospitalized patients, what are the effects of a universal screening strategy for MRSA-carriage (screen, isolate, eradicate/decolonize) – when compared with no screening?
Key Question 2 Among ambulatory or hospitalized patients, what are the effects of a universal screening strategy for MRSA-carriage (screen, isolate, eradicate/decolonize) – when compared with targeted screening?
Key Question 3 a. Among ambulatory or hospitalized patients, what are the effects of screening ICU patients for MRSA-carriage (screen, isolate, eradicate/decolonize) – when compared with no screening?
  b. Among ambulatory or hospitalized patients, what are the effects of screening surgical patients for MRSA-carriage (screen, isolate, eradicate/decolonize) – when compared with no screening?
  c. Among ambulatory or hospitalized patients, what are the effects of screening high-risk patients for MRSA-carriage (screen, isolate, eradicate/decolonize) – when compared with no screening?
Key Question 4 Among ambulatory or hospitalized patients, what are the effects of an expanded screening strategy for MRSA-carriage (screen, isolate, eradicate/decolonize) – when compared with a limited screening strategy.1

The outcomes of interest for each of above questions were:

- Intermediate outcomes such as health care-acquired (HA)-MRSA transmission (as measured by new acquisition events).
- Health outcomes such as the incidence of HA-MRSA infection, morbidity (including complications of MRSA infection), mortality, adverse events (including allergic and non-allergic toxicity (e.g., hypotension), antimicrobial resistance, reduced quality of care, and medical errors), and hospital resource utilization such as length of stay.1

For the four different screening strategies evaluated: (1) universal screening compared with no screening; (2) universal screening compared with targeted screening of selected patient populations; (3) targeted screening of selected patient populations compared with no screening; and (4) expanded screening compared with limited screening, the CER found insufficient evidence to determine the comparative effectiveness of MRSA screening on MRSA acquisition, infection, morbidity, mortality, harms and resource utilization.1 Two analytical frameworks that guided the CER are provided in Figure 1 and Figure 2. Figure 1 depicts the effects of screening for MRSA-carriage on intermediate outcomes (including MRSA acquisition) and health outcomes (including MRSA infection, morbidity and mortality); and Figure 2 depicts the effects of screening for MRSA carriage in detail. Appendix A provides the summary of outcomes measures and strength of evidence of the included studies in the draft CER.1

Figure 1 Analytic framework for MRSA screening

KQ = Key Question; MRSA = methicillin-resistant Staphylococcus aureus

Figure 1 is the analytic framework that depicts the effects of screening for MRSA-carriage on intermediate outcomes (including MRSA acquisition) and health outcomes (including MRSA infection, morbidity and mortality).

Figure 2 Detailed analytic framework for MRSA screening

KQ = Key Question; MRSA = methicillin-resistant Staphylococcus aureus

Figure 2 is the detailed analytic framework that depicts the effects of screening for MRSA carriage in detail. Once screened, patients may or may not be isolated while waiting for screening test results. Once the screening test results are received, patients who screen positive may be isolated; patients who screen negative are not. Eradication/decolonization may be attempted in patients who screen positive. Intermediate outcomes of MRSA screening, including MRSA transmission, are depicted in the figure. Health outcomes, including MRSA infection, morbidity and mortality, are also depicted. The figure illustrates the potential harms of screening, including decreased room availability, decreased attention from health care personnel, antibiotic resistance, allergic reactions, and nonallergic toxicity.

### Evidence Gaps

The CER identified a number of limitations in the evidence that prevents precise estimates of the comparative effectiveness of screening for MRSA-carriage on infection rates, morbidity and mortality.1 Insufficient numbers of patients were enrolled in studies to be adequately powered to detect the effect of screening for MRSA-carriage compared with no screening or to screening of selected patient populations on morbidity and mortality. There is a paucity of rigorous, well-controlled studies employing uniform or even standardized microbiological and infection control techniques.1 Inconsistency in the definition, application and measurement of the interventions commonly bundled together with MRSA screening limits the conclusions that can be drawn about the attributable benefit of screening compared with any other component of the infection control strategy such as more rigorous hand hygiene, barrier precautions, environmental cleaning, and antimicrobial decolonization.1

Studies failed to take a more uniform approach to the testing strategy used (e.g., PCR vs. culture), address test turn-around time, or account for the management of patients before screening test results are known.1 The existing evidence failed to quantify and account for the potential bias introduced by secular trends that may contribute to variation in the incidence of infectious diseases over time.1 Secular trends may include infection outbreaks, deviations and departures from best practice, dissemination of new prevention practices, changes in antibiotic prescribing, seasonal influences, or even the application of other interventions that may influence transmission or infection.

The evidence failed to account for the influence of concomitant infection prevention strategies and treatment interventions or staff compliance with them.1 Omission of interventions such as institutional initiatives to improve hand hygiene and promote an institutional culture of safety, which have been shown to influence the frequency of many health care-associated infections, may be important. However, it is unrealistic to believe that a standardized and uniform approach can be recommended and applied to all future studies of screening for MRSA-carriage. Lacking such a standard, a maximally transparent approach to reporting interventions and potential confounders would be absolutely critical.1

There is a near complete absence of systematic evidence regarding the potential harms of screening for MRSA-carriage. Patients identified as MRSA-positive through screening programs may require isolation, potentially limiting the number of available beds at any given hospital, which, in turn, may decrease the number of patients who can be served locally, regionally and nationally. Because community-dwelling residents may develop health-care associated MRSA infection and because hospitalized patients may develop community-associated MRSA infection, understanding the benefits and harms of screening for MRSA in the outpatient setting is of increasing importance.6,7 Perhaps most importantly, the harms of screening compared with no screening must be clearly delineated to determine the comparative effectiveness of screening for MRSA-carriage. To attempt to measure the favorable impact of screening for MRSA-carriage while ignoring its potential risks is to present incomplete and potentially misleading data.