# Executive Summary

## Background

Methicillin-resistant Staphylococcus aureus (MRSA) emerged as a clinically relevant human pathogen more than 5 decades ago.1 The virulent bacterium was first detected in hospitals and other health care facilities where vulnerable hosts, frequent exposure to the selective pressure of intensive antimicrobial therapy, and the necessity for invasive procedures created a favorable environment for dissemination. MRSA emerged as an important cause of health care-acquired infections, particularly central line-associated bloodstream infection, ventilator-associated pneumonia, and surgical site infection.

Despite the adoption of infection control measures, the incidence of MRSA infection at most hospitals in the United States (U.S.) steadily increased for many years, but is now decreasing. Routine clinical cultures may miss a large portion of patients who are silent carriers of these organisms and serve as reservoirs for further transmission. More aggressive measures have been sought to check the spread of this particularly virulent pathogen. Active surveillance screening for MRSA is receiving greater attention for its potential value in identifying carriers of MRSA to prevent further transmission.

To identify the population of colonized individuals, microbiological samples are obtained from at-risk patients even in the absence of signs or symptoms of infection. The screening strategy may use a testing modality with a rapid turnaround time (results available on the same day as the testing is performed, typically using polymerase chain reaction (PCR), intermediate turnaround time (results available next day to 2 days after testing performed) or longer turnaround time (results available greater than 2 days after testing performed, typically culture). Because screening alone is not expected to affect health outcomes, screening strategies may include screening with or without isolation and with or without attempted decolonization or eradication. By detecting the larger population of colonized individuals, at the very least conventional precautions (i.e., hand hygiene and contact isolation) can be implemented in a broader and timelier manner to interrupt horizontal transmission of MRSA. Detection of colonized patients also permits consideration of more aggressive interventions, including attempts at microbiological eradication or decolonization.

A Comparative Effectiveness Review (CER) was prepared by the Blue Cross and Blue Shield Association Technology Evaluation Center Evidence-based Practice Center (BCBSA TEC EPC) on Screening for Methicillin-Resistant Staphylococcus aureus (MRSA).1 The objective of the CER was to synthesize comparative studies that examined the benefits or harms of screening for MRSA carriage in the inpatient or outpatient settings.1 The review examined MRSA-screening strategies applied to all hospitalized or ambulatory patients (universal screening), as well as screening strategies applied to selected inpatient or outpatient populations (e.g., patients admitted to the intensive care unit (ICU), patients admitted for a surgical procedure, or patients at high-risk of MRSA colonization or infection such those on prolonged antibiotic therapy) and compared them to no screening or to screening of selected patient populations (targeted screening). The review evaluated MRSA-screening strategies with or without isolation and with or without attempted eradication/decolonization.

The following four Key Questions formed the basis for the CER:

Key Question 1 Among ambulatory or hospitalized patients, what are the effects of a universal screening strategy for MRSA-carriage (screen, isolate, eradicate/decolonize) – when compared with no screening?
Key Question 2 Among ambulatory or hospitalized patients, what are the effects of a universal screening strategy for MRSA-carriage (screen, isolate, eradicate/decolonize) – when compared with targeted screening?
Key Question 3 a. Among ambulatory or hospitalized patients, what are the effects of screening ICU patients for MRSA-carriage (screen, isolate, eradicate/decolonize) – when compared with no screening?
  b. Among ambulatory or hospitalized patients, what are the effects of screening surgical patients for MRSA-carriage (screen, isolate, eradicate/decolonize) – when compared with no screening?
  c. Among ambulatory or hospitalized patients, what are the effects of screening high-risk patients for MRSA-carriage (screen, isolate, eradicate/decolonize) – when compared with no screening?
Key Question 4 Among ambulatory or hospitalized patients, what are the effects of an expanded screening strategy for MRSA-carriage (screen, isolate, eradicate/decolonize) – when compared with a limited screening strategy?1

Two analytical frameworks that guided the CER are provided in Figure A and Figure B: Figure A depicts the effects of screening for MRSA-carriage on intermediate outcomes (including MRSA acquisition) and health outcomes (including MRSA infection, morbidity and mortality); and Figure B depicts the effects of screening for MRSA carriage in detail.

Figure A Analytic framework for MRSA screening

KQ = Key Question; MRSA = methicillin-resistant Staphylococcus aureus

Figure A is the analytic framework that depicts the effects of screening for MRSA-carriage on intermediate outcomes (including MRSA acquisition) and health outcomes (including MRSA infection, morbidity and mortality).

Figure B Detailed analytic framework for MRSA screening

KQ = Key Question; MRSA = methicillin-resistant Staphylococcus aureus

Figure B is the detailed analytic framework that depicts the effects of screening for MRSA carriage in detail. Once screened, patients may or may not be isolated while waiting for screening test results. Once the screening test results are received, patients who screen positive may be isolated; patients who screen negative are not. Eradication/decolonization may be attempted in patients who screen positive. Intermediate outcomes of MRSA screening, including MRSA transmission, are depicted in the figure. Health outcomes, including MRSA infection, morbidity and mortality, are also depicted. The figure illustrates the potential harms of screening, including decreased room availability, decreased attention from health care personnel, antibiotic resistance, allergic reactions, and nonallergic toxicity.

Four different screening strategies were evaluated: (1) universal screening compared with no screening; (2) universal screening compared with targeted screening of selected patient populations; (3) targeted screening of selected patient populations compared with no screening; and (4) expanded screening compared with limited screening. The draft CER found insufficient evidence to determine the comparative effectiveness of MRSA screening on MRSA acquisition, infection, morbidity, mortality, harms and resource utilization.

The draft CER identified evidence gaps related to the effectiveness of MRSA screening. The context in which screening is implemented (e.g., prior multidrug resistance organism control programs and the safety culture of the health care institution) lacked consistent and transparent documentation making it difficult to assess the full impact of screening. Knowledge of epidemiologic trends and inconsistency in the definition, application and measurement of the interventions commonly bundled together with MRSA screening limited interpretation of the available evidence. It is possible that a single component of a MRSA screening strategy, for example the decolonization of patients found through screening to be MRSA-positive, may produce an independent, clinically significant benefit, but the influence of other important factors such as the testing strategy (e.g., PCR vs. culture) and knowledge of its corresponding test turn-around time, management of patients before screening test results are known, and the use of concomitant infection prevention strategies and treatments could not be determined.

Precise estimates of the comparative effectiveness of screening for MRSA-carriage on morbidity and mortality are lacking. Studies failed to enroll sufficient numbers of patients to be adequately powered to detect the effect of screening for MRSA-carriage compared with no screening or to screening of selected patient populations on morbidity and mortality. Perhaps most importantly, the harms of screening were not clearly delineated, particularly in the outpatient setting. Since community-dwelling residents may develop health-care acquired MRSA infection and hospitalized patients may develop community-acquired MRSA infection, understanding both the benefits and harms of screening for MRSA is of increasing importance. However, the evidence in the draft CER focused largely on the benefits of screening, thereby presenting an incomplete picture of the full impact of screening for MRSA-carriage.

## Methods

First, evidence gaps were identified through the BCBSA TEC EPC CER. The literature search was updated and clinicaltrials.gov was searched to identify any ongoing or recently published research studies that might address the evidence gaps. A group of 10 stakeholders (Stakeholder Panel) was convened, representing diverse clinical perspectives including methodological/research expertise, clinical experience, and consumer and payer representation. The Stakeholder Panel prioritized each research need and corresponding research questions using an online survey tool called SurveyMonkey^®^.

The project team modified the Effective Health Care (EHC) Program Selection Criteria to be applicable to primary research rather than to systematic reviews of original research. The Stakeholder Panel used the modified selection criteria to prioritize both research needs and corresponding research questions. We compiled a final list, taking the Panel members’ comments into consideration and paying particular attention to areas where ongoing efforts might overlap with prioritized research questions. The research questions were characterized using the PICOTS framework consisting of the population(s) (P), interventions (I), comparators (C), outcomes (O), timing (T), and settings (S). The project team then evaluated potential study designs to address each of the prioritized research questions in accordance with the recent Future Research Needs methods report authored by the RTI-UNC Evidence-based Practice Center (EPC) commissioned by the Agency for Healthcare Research and Quality (AHRQ).2 The Stakeholder Panel provided insight into how future research agendas and proposed studies to address the research needs fit within these pre-specified criteria.

## Results

A total of seven research needs were identified through a combination of the CER findings and conversations with the Stakeholder Panel. These research needs are stated in Table A (in order of priority).

Table A Prioritized list of research needs

1. What are the central components of a MRSA screening strategy?; 2. Who may benefit from MRSA screening?^*^; 3. What outcomes should be considered for evaluations of MRSA screening?^*^; 4. What are the most effective tests for MRSA screening?; 5. What factors could influence MRSA test results (e.g., when to screen, which sites to swab)?; 6. What are the appropriate comparators for MRSA screening?; 7. From which perspective(s) should evaluations of MRSA screening be conducted (e.g., societal, hospital, emergency room, patient, payer)?

MRSA = methicillin-resistant Staphylococcus aureus

* Both questions received equal votes.

These seven research needs were considered priorities because the information at present is insufficient or imprecise and precludes conclusions about the effectiveness of, and need for, MRSA screening. While acknowledging that the research needs are interrelated, their ranking reflected the major issues the Stakeholder Panel felt needed to be addressed to understand the context in which MRSA screening may be effective. The Stakeholder Panel then generated and prioritized a list of potential research questions that incorporated the research needs. The research questions included the patient populations the Panel members felt would most likely benefit from MRSA screening. They are surgical admissions, general medical inpatients and intensive care populations. The final prioritized list of research questions are presented in Table B.

Table B Prioritized list of research questions

1. For surgical admissions, what is the most effective strategy for reducing MRSA acquisition and infection rates and improving morbidity, mortality, patient flow and resource use?; 2. For surgical admissions what factors are associated with increased risk of MRSA acquisition and infection?; 3. For intensive care populations, what is the most effective strategy for reducing MRSA acquisition and infection rates and improving morbidity, mortality, patient flow and resource use?; 4. For the neonatal intensive care setting, what is the most effective strategy for reducing MRSA acquisition and infection rates and improving morbidity, mortality, patient flow and resource use?; 5. For intensive care populations, what factors are associated with increased risk of HA-MRSA acquisition and infection?; 6. For general medical inpatients, what is the most effective strategy for reducing MRSA acquisition and infection rates and associated morbidity, mortality, patient flow and resource use?; 7. For general medical inpatients, what factors are associated with increased risk of HA-MRSA acquisition and infection?

HA = hospital acquired; MRSA = methicillin-resistant Staphylococcus aureus

For the assessment of study designs, the project team evaluated the appropriateness of various designs for each prioritized research question and incorporated Stakeholder Panelists’ considerations for future research into PICOTS (populations, interventions, comparators, outcomes, timing, and settings) elements. For questions 2, 5, and 7 epidemiological studies offer the most valid and practical approaches to quantifying the relationship between factors associated with the increased risk of MRSA acquisition and infection. They are: cohort studies; nested case-control or case-control studies; and cross-sectional studies. These prioritized research questions along with PICOTS elements are presented in Table C.

Table C Prioritized list of risk factor research questions with PICOTS information

Research Question | Population(s) | Interventions | Comparators | Outcomes | Timing | Settings
2. For surgical admissions what factors are associated with increased risk of MRSA acquisition and infection? | Full or representative sample of surgical admissions:; - Ambulatory care/ED admissions; - Surgical unit admissions; - Elective admissions | - MRSA screening/culture; - Surveillance of potential risk factors for MRSA acquisition or infection (e.g., interview, questionnaire, database) | - No screening; - Surveillance of potential risk factors for MRSA acquisition or infection (e.g., interview, questionnaire, database) | - MRSA surgical site infection rate; - MRSA acquisition rates; - Risk factors for MRSA acquisition; - Risk factors for MRSA infection | - On admission (e.g., in the ED or surgical unit); - Pre-admission; - At discharge; - At followup visit | - Inpatient; - Outpatient; - Non-outbreak setting
5. For intensive care populations, what factors are associated with increased risk of HA-MRSA acquisition and infection? | Full or representative sample of intensive care admissions with the potential to acquire MRSA. May come from:; - Ambulatory care/ED; - General inpatient population | - MRSA screening/culture; - Surveillance of potential risk factors for MRSA acquisition or infection (e.g., interview, questionnaire, database) | - No screening; - Surveillance of potential risk factors for MRSA acquisition or infection (e.g., interview, questionnaire, database) | - MRSA acquisition; - Risk factors for MRSA acquisition; - MRSA infection; - Risk factors for MRSA infection | - On admission (e.g., in the ED or ICU) | - Inpatient; - Non-outbreak setting
7. For general medical inpatients, what factors are associated with increased risk of HA-MRSA acquisition and infection? | Full or representative sample of general medical admissions with the potential to acquire MRSA. May come from:; - Ambulatory care/ED; - Elective admissions | - MRSA screening/culture; - Surveillance of potential risk factors for MRSA acquisition or infection (e.g., interview, questionnaire, database) | - No screening; - Surveillance of potential risk factors for MRSA acquisition or infection (e.g., interview, questionnaire, database) | - MRSA acquisition; - Risk factors for MRSA acquisition; - MRSA infection; - Risk factors for MRSA infection | - On admission (e.g., in the ED or to the ward) | - Outpatient (for elective admissions); - Inpatient; - Non-outbreak setting

ED = emergency department; HA = hospital acquired; ICU = intensive care unit; MRSA = methicillin-resistant Staphylococcus aureus; PICOTS = population(s), interventions, comparators, outcomes, timing, settings

On the other hand, for questions 1, 3, 4 and 6 that address the effectiveness of MRSA screening, experimental designs are needed to determine the causal effect of MRSA screening strategies on patient outcomes. The optimal design would allow the researcher to address multiple research needs by manipulating one or more variables and controlling and measuring their effects on other variables, while balancing the feasibility and practicality of carrying out the design. The project team proposed the following study designs: cluster randomized controlled trials; quasi-experimental (before-after) studies; and modeling. These prioritized research questions are accompanied with PICOTS elements in Table D.

Table D Prioritized list of effectiveness research questions with PICOTS information

Research Question | Population(s) | Interventions | Comparators | Outcomes | Timing | Settings
1. For surgical admissions, what is the most effective strategy for reducing MRSA acquisition and infection rates and improving morbidity, mortality, patient flow and resource use? | - Broad range of risk categories (low, medium, high) for universal screening strategies or; - High risk populations for targeted screening strategies | - Screening-based strategy (e.g., screening and decolonization) + standard care precautions; Types of MRSA screening tests to be considered:; - Multiplex PCR; - Culture; Site(s) of MRSA screening:; - Nares, throat, axilla, groin, perirectal; - Optimal number of sites to swab; - Optimal anatomical sites; - Separate swabs for each site vs. one swab for all sites | - Non-screening test based strategy (e.g., gowning and gloving, hand hygiene, or standard care precautions) | - MRSA surgical site infection rate; - Staff compliance with infection control procedures; - Patient flow (e.g., median time interval between ED arrival and hospital admission); - Morbidity (e.g., complications of MRSA infection); - MRSA-attributable mortality; - Harms (e.g., allergic reaction to treatment, satisfaction of patients in isolation); - Resource use (e.g., length of stay); - Turn-around times for test results; - Cost-benefit analysis | - Time point at which screening is done (e.g., admission in ambulatory care or surgical unit); - Time point at which intervention is initiated based on screening results; - Time point at ED arrival; - Time point at hospital admission | - Inpatient (e.g., ambulatory care/ED, surgical unit); - Outpatient; - Non-outbreak setting
3. For intensive care populations, what is the most effective strategy for reducing MRSA acquisition and infection rates and improving morbidity, mortality, patient flow and resource use? 4. For the neonatal intensive care setting, what is the most effective strategy for reducing MRSA acquisition and infection rates and improving morbidity, mortality, patient flow and resource use? | - Broad range of risk categories (low, medium, high) for universal screening strategies or; - High risk populations for targeted screening strategies | - Screening-based strategy (e.g., screening and decolonization) + standard care precautions; Types of MRSA screening tests to be considered:; - Multiplex PCR; - Culture; Site(s) of MRSA screening:; - Nares, throat, axilla, groin; - Optimal number of sites to swab; - Optimal anatomical sites; - Separate swabs for each site vs. one swab for all sites | - Non-screening based strategy (e.g., gowning and gloving, hand hygiene, or standard care precautions only) | - MRSA acquisition rate; - MRSA infection rate; - Staff compliance with infection control procedures; - Patient flow (e.g., median time interval between ED arrival and hospital admission); - Morbidity (e.g., complications of MRSA infection); - MRSA-attributable mortality; - Harms (e.g., allergic reaction to treatment, satisfaction of patients in isolation); - Resource use (e.g., length of stay); - Turn-around times for test results; - Mother-to-child transmission rate (for neonates only); - Cost-benefit analysis | - Time point at which screening is done (e.g., admission in ambulatory care or on ward); - Time point at which intervention is initiated based on screening results; - Time point at ED arrival; - Time point at hospital admission | - Inpatient (e.g., ambulatory care/ED, ICU, labor and delivery); - Non-outbreak setting
6. For general medical inpatients, what is the most effective strategy for reducing MRSA acquisition and infection rates and associated morbidity, mortality, patient flow and resource use? | - Broad range of risk categories (low, medium, high) for universal screening strategies or; - High risk populations for targeted screening strategies | - Screening-based strategy (e.g., screening and decolonization) + standard care precautions; Types of MRSA screening tests to be considered:; - Multiplex PCR; - Culture; Site(s) of MRSA screening:; - Nares, throat, axilla, groin; - Optimal number of sites to swab; - Optimal anatomical sites; - Separate swabs for each site vs. one swab for all sites | - Non-screening based strategy (e.g., gowning and gloving, hand hygiene, or standard care precautions only) | - MRSA acquisition rate; - MRSA infection rate; - Staff compliance with infection control procedures; - Patient flow (e.g., median time interval between ED arrival and hospital admission); - Morbidity (e.g., complications of MRSA infection); - MRSA-attributable mortality; - Harms (e.g., allergic reaction to treatment, satisfaction of patients in isolation); - Resource use (e.g., length of stay); - Turn-around times for test results; - Cost-benefit analysis | - Time point at which screening is done (e.g., admission in ambulatory care or on ward); - Time point at which intervention is initiated based on screening results; - Time point at ED arrival; - Time point at hospital admission | - Inpatient (e.g., ambulatory care/ED, ward); - Outpatient for elective admissions; - Non-outbreak setting

ED = emergency room; ICU = intensive care unit; MRSA = methicillin-resistant Staphylococcus aureus; PCR = polymerase chain reaction; PICOTS = population(s), interventions, comparators, outcomes, timing, settings

## Discussion and Conclusions

This Future Research Needs project was developed to address important evidence gaps identified in the BCBSA TEC EPC CER. A multidisciplinary Stakeholder Panel of 10 participants used an 11-step process to identify and prioritize research needs and key research questions across the selected research needs. The final research questions reflect the research needs in the evidence related to the key populations identified in the CER and by the Stakeholder Panel.

We used multiple techniques to engage stakeholders, including individual interviews, online surveys and conference calls. The literature search update allowed for more informed decisions in selecting topics that were not duplicative with current ongoing trials and to which further research would add the greatest value.

It should be noted that the Stakeholder Panel brought forth research needs that were outside the scope of the original review, such as the need to address methicillin-susceptible Staphylococcus aureus (MSSA). Strategies found to be effective in reducing hospital-acquired (HA) MRSA infection would likely reduce HA MSSA. Future study designs could pre-specify MRSA and MSSA as different subgroups. Panel members emphasized the need for further basic epidemiological investigation to identify groups at high-risk for MRSA infection which would help target and design appropriate interventions. The Stakeholder Panel suggested that two questions ranked as lower priorities might also be considered as future research needs. First, in terms of burden of infection and high public health impact, the question addressing the most effective strategy for preventing MRSA infection among carriers after discharge from the hospital would benefit from further research to address the appropriate prevention strategy in this population. Second, determining the most effective anatomical-site screening protocol for detecting MRSA and MSSA carriage especially in high-risk surgical patients is presently an “under-studied” area in need of further research.

One of the major challenges we encountered in our process was the various ways to combine/categorize many of the proposed topics; there was overlap among the various research needs and key underlying research questions given their inter-relatedness. In addition, it was important to maintain the focus on the research needs in the evidence (and scope) addressed in the CER. A limitation of this process was that the Stakeholder Panel was presented with the draft results of the CER during the prioritization process; the conclusions did change between the draft and the final version, and thus the impact of these changes on the rankings of the research needs is unknown.

## References

1 Glick SB, Webber S, Huang E, et al. Screening for Methicillin-Resistant Staphylococcus aureus (MRSA). Comparative Effectiveness Review No. 102. (Prepared by the Blue Cross and Blue Shield Technology Evaluation Center Evidence-based Practice Center under Contract No. 290-2007-10058-I.). AHRQ Publication No. 13-EHC043-EF. Rockville, MD. Agency for Healthcare Research and Quality. Forthcoming 2013. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
2 Carey T, Sanders GD, Viswanathan M, et al. Framework for Considering Study Designs for Future Research Needs. Methods Future Research Needs Paper No. 8. (Prepared by the RTI–UNC Evidence-based Practice Center under Contract No. 290-2007-10056-I.) AHRQ Publication No. 12-EHC048-EF. Rockville, MD. Agency for Healthcare Research and Quality. March. 2012. www.effectivehealthcare.ahrq.gov/reports/final.cfm.