# Stakeholder Panel

The following individuals served as members of the Stakeholder Panel described in this report. Their contributions were invaluable. They were given the opportunity to review the report during the public comment period.

- Gordon Archer, M.D.
  Virginia Commonwealth University
  Richmond, VA
- Jennifer Chambers, M.D., M.B.A.
  Capital BlueCross
  Harrisburg, PA
- Kathleen Day, R.N.
  Consumer/patient advocacy
- Nathan Dean, M.D.
  University of Utah
  Murray, UT
- Anthony Harris, M.D., M.P.H.
  University of Maryland
  Baltimore, MD
- John Jernigan, M.D.
  Centers for Disease Control and Prevention
  Atlanta, GA
- Sheldon Kaplan, M.D.
  Texas Children’s Hospital
  Houston, TX
- Catherine Liu, M.D.
  University of California, San Francisco
  San Francisco, CA
- Gregory Moran, M.D.
  Olive View-UCLA Medical Center
  Sylmar, CA
- Melinda Rowe, M.D., M.P.H., M.B.A.
  Alabama Medicaid Agency
  Montgomery, AL